# Discussion

Ultimately, the goal of systematic reviews is to provide a synthesis of information that: is useful to clinicians and patients in determining which interventions would be most effective for their context; informs hospital leaders which interventions are most likely to achieve better results in their system; and provides policymakers with the information they need to make sound decisions to improve societal health and the health care system. Achieving these goals is a particularly daunting task when the question of interest involves complex multicomponent health care interventions. As recently demonstrated, the number of challenges reviewers face can fill an entire journal supplement: starting at the level of terminology (e.g., use of the word complex as a descriptor) and extending to approaches to framing of the review and analyses.54-61

The series of articles in the referenced journal supplement,54-61 along with the current literature outlined in this paper, point to the currency of this topic and the need for guidance. This paper and the series of articles were developed in parallel, and have the benefit of two related but separate groups considering and fleshing out the issues on this important topic. While aspects of the referenced supplement and this paper overlap, this paper has the added benefits of the input of KIs complementing a systematic literature scan on the topic. The KIs not only included researchers and systematic review methodologists who have conducted reviews of complex multicomponent health systems interventions, but also health systems leaders who use reviews to guide their decisionmaking regarding implementation of multicomponent interventions. In particular, the inclusion of individuals involved in implementing and evaluating complex interventions provided insight about aspects to improve the usefulness and relevance of reviews of complex multicomponent interventions. In addition, this paper differs in intent from the recently-published supplement referenced; it was developed by investigators across the EPC program and is intended to inform guidance on how best to develop feasible, rigorous, and useful reviews in a consistent manner within and across the 11 centers, given the EPC program's requirements and policy and care delivery in the United States.

We agree with Cochrane's recent statement that, “A more precise and consistently applied lexicon and language to disaggregate the conceptually distinct dimensions of complexity will advance the development of methods to investigate each in systematic reviews.”54 The inconsistency in terminology used to describe complex multicomponent interventions can hamper searches to identify relevant studies and can erect barriers when communicating with stakeholders during the development of the topic as well as reporting the final results. It is important for reviews in this area to define the terms they use early in the report and for searches to consider all possible terms. We also agree that engaging stakeholders early in the process of the systematic review to assist with framing, scoping, and Key Question development is critical, and this was affirmed in our KI interviews with implementers and primary researchers examining complex interventions. Furthermore, the input of KIs to this paper provided valuable insight into the perspective of users of systematic reviews. For example, implementers and evaluators of complex interventions noted that definition of the term “complex intervention” or the use of PICOTS was less important than providing clear definitions of interventions examined in primary studies and systematic reviews to improve the applicability and reproducibility of the study findings. This includes describing critical elements of how the studied interventions were implemented, as well as the relevant contextual features inherent to the setting of implementation.

Approaches that have been used for reviews of complex multicomponent interventions range from the holistic approach to detailed analyses of specific components or features to theoretical models where the results of studies are overlaid onto a framework. Although we did not provide guidance about how to choose an approach, we noted that the choice of approach may be influenced not only by the intent of the systematic review and judgment by the investigator about the nature of the intervention, but also the available literature and appropriate analytic approaches. In addition, the clinical logic and context of a topic may also influence the approach. While RCTs may give the best representation of the overall effectiveness of an intervention, non-RCTs may be helpful in identifying implementation considerations and understanding why interventions worked or did not work in certain settings. The incorporation of qualitative studies in systematic reviews is another area where guidance is needed. Ultimately, conversations with stakeholders and experts in the field are important early in the conduct of a review to provide a basic understanding of what is known in the specific field, what is needed, and what framing, reporting, and analytic approaches will be best understood by users.

…all these health care systems are in the process of putting together a very expensive, very difficult, very onerous intervention with almost no data, and I think AHRQ made the wise decision to say, look, this is not perfect, we're still dealing with field and evolution, but this is a snapshot of what the current state of data are at this point in time.

As reflected in the statement above by one of our KIs and echoed by others, reviews of complex, multicomponent interventions are valuable, in spite of the evolving nature of the field and unresolved challenges. Reviews can summarize an evidence base, which is valuable to researchers, implementers, and policymakers. However, reviewers are limited in what they are able to report because of limitations in what is reported in the literature itself. For this reason, KIs reported that having a shared understanding of what should be reported in studies of complex multicomponent interventions, either in published reports or electronic appendixes would help advance the field. This common understanding would pertain both to primary studies of complex multicomponent interventions for what they should report and systematic reviews for what they should consider and abstract from included studies. The list of reporting elements generated for this paper provides a starting point for reaching this common understanding.

## Next Steps

1. As reflected in our literature scan and by our input from KIs, many terms were in use with overlapping definitions. The use of consistent terminology would benefit future efforts in developing methods for synthesizing information on multicomponent interventions.
2. Comparisons of the value to end-users of different approaches to synthesis on the same topic (for example, a retrospective analysis of two different review approaches to the same topic).
3. Explore and test new analytic approaches to the systematic review of multicomponent interventions that have been used to evaluate complexity in other disciplines (for example, qualitative comparative analysis).
4. Disseminate and implement knowledge of critical reporting elements for primary or secondary evaluations of multicomponent interventions. Audiences may include EPCs, Cochrane, and other reviewers and end users.

## Conclusions

Systematic reviews of the evidence aim to present benefits and harms for interventions clearly so that decisionmakers can fairly assess the important considerations and tradeoffs when determining which interventions should be adopted in their setting. Systematic reviews of complex multicomponent interventions for any clinical topic pose many challenges, some due to inconsistency in the field, but many due to limitations in reporting of primary studies of complex multicomponent health care interventions. Ultimately, decisions about approach and underlying questions for the review depend upon the robustness of the literature and end-user needs for the particular area. Clarifying the systematic review's guiding framework, as well as its terminology, can ensure sensitivity to the important clinical questions. They also lead to context-dependent decisions about literature types to search, study designs to include, and analytic approaches to consider. Finally, presenting the review with key reporting elements included will allow users to make important decisions about applying findings from a review of complex multicomponent intervention to their local settings.