# Background

The Agency for Healthcare Research and Quality (AHRQ)'s Effective Health Care program is increasingly receiving requests from stakeholders to synthesize evidence regarding the effectiveness and harms of complex multicomponent health care interventions. Examples of such interventions include quality improvement, infection control, and health care informatics interventions. For instance, studies that evaluate screening for the health care-associated infection Methicillin-resistant Staphylococcus aureus (MRSA) commonly perform screening together with a bundle of interventions including contact isolation (placing patients suspected of harboring MRSA in private rooms and requiring persons who have contact with them to wear gowns and gloves) and decolonization (using antibiotics to try to disinfect the patient). Systematic reviews of complex, multicomponent interventions provide clinicians, policymakers, and others with needed information about the benefits and harms of the interventions so that decisions can be made about whether or not to implement them. However, because of their complexity, conducting reviews on multicomponent interventions is often challenging.

A number of features distinguish complex multicomponent health care interventions from those more commonly examined in the literature, like devices or pharmaceuticals. First, these interventions are most commonly implemented at the level of an inpatient unit, outpatient clinic, hospital, or health system, rather than the level of an individual patient. Because setting characteristics such as culture or staffing levels may interact with the intervention of interest, it can become critical to understand and enumerate those aspects of the setting that may modify the interventions' effects and synthesize the available interventions in the context of those factors. Second, these interventions by definition include more than one component and it may be uncommon for any two studies to examine identical combinations of components. This is particularly true as multicomponent interventions evolve over time and researchers examining the interventions add or remove components based on their ongoing experience with the bundle. Thus, systematic reviewers need guidance for deciding which interventions are sufficiently similar to be combined. Third, the “complexity” of multicomponent health care interventions implies that the interventions cannot be reduced to the sum of their individual components, but rather should be analyzed as “systems” themselves. This challenges reviewers to identify those components essential to the intervention from those that are superfluous. Ultimately, the generalizability and usability of findings from syntheses of studies of complex multicomponent health care interventions will be limited unless the reviewer has an appreciation for and can address the challenges listed above.1

The purpose of this report is to outline approaches to address the challenges of conducting systematic reviews of complex multicomponent health care interventions such that reviewers can produce the most valid and actionable analyses possible. This report is not presented as guidance, but rather as an overview of pertinent issues, and as a first step towards the eventual development of Evidence-based Practice Center (EPC) guidance.