# Analytic Models and Description of Synthesis Options

Table D-1 Description of synthesis options

# | Description | Example | Some Key Assumptions (not a complete list)^a^ | Disadvantages | Synthesis Format | Utilizes Framework-Imposed Structure
1 | Any intervention instantiation vs. ‘usual care’ (holistic) | - Decision aids for people facing treatment decisions^b^; - Collaborative care for management of depression in primary care^c^ | - All intervention instantiations have exchangeable effects; - The controls are comparable | - The summary effect may not be applicable | Qualitative Quantitative | No
2 | Compare subclasses of intervention instantiations (subgroups of mutually exclusive subgroups of interventions) | - Pulmonary rehabilitation interventions for chronic obstructive pulmonary disease | [Additional assumptions over #1]; - Intervention instantiations are exchangeable within a subclass; - Subclass effects are exchangeable; - Between-subclass differences are consistent | - May need more studies than #1; - Between-class comparisons may not be observed; - Challenging to do qualitatively | Qualitative Quantitative | Yes – grouping interventions in classes
3 | Explain interventions by specific characteristics of interventions/components | - Quality improvement and knowledge transfer interventions for diabetes management^d^ | [Additional assumptions over #1]; - Total effect is decomposed as a function of component effects. | - May need large number of studies; - Some effects may not be identifiable; - Challenging to do qualitatively | Qualitative Quantitative | Yes– decomposition of main effects into component effects

a Assumptions specific to an analysis choice (e.g., network meta-analysis, or vote counting) are not listed.

b Stacey D, Bennett CL, Barry MJ, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev. 2011;10(10). .

c Bower P, Gilbody S, Richards D, et al. Collaborative care for depression in primary care. Making sense of a complex intervention: systematic review and meta-regression. Br J Psychiatry. 2006;189:484-93. [pmid: 17139031]. .

d Tricco AC, Ivers NM, Grimshaw JM, et al. Effectiveness of quality improvement strategies on the management of diabetes: a systematic review and meta-analysis. Lancet. Jun. 16. 2012;379(9833):2252-61. [pmid: 22683130]. .