# Selected Quotes From Interviews

Table C-1 Terminology

Comments on the importance of defining one's terms
“I think having some clarity or beginning to get clarity on what each of the terms mean would be a huge advantage for the field.”
“I think you need to distinguish between multicomponent interventions, which typically are complex and complex interventions which can include a number of other dimensions of complexity besides having multiple components. (dimensions included behaviors or actions of recipients, degree of flexibility/adaptability, skills needed to deliver intervention, skills required of people targeted by intervention, interaction between components, interaction between intervention and context, how complex is causal pathway from intervention to outcome).”
“I think it is important to have clear definitions and taxonomies about what we're talking about because the current state where people are talking about the same thing and different things using different words isn't actually helpful.”
“Depending on the discipline of the literature you're looking at, those terms were used interchangeably, so I think it's hard to get real rigid about … particularly if you're going to take a multidisciplinary approach in looking at the evidence.”
“I don't really have strong feelings about it. For me, I know there's this whole complexity science movement, and I think any social science intervention, for the most part, is complex. So to me I'm not that bothered by the different names.”
“I also think that we make too big a deal on naming things, as opposed to looking at what they're composed of.”
“I think we found in XXX (topic) the terminology and semantics very challenging”; “I think we don't have very precise terminology around the term complex, and also it's applied often dually or in a confusing fashion to the description of the patient as well as a description of the intervention. I don't have strong feelings about how it's used, but I do think that being precise on terminology does matter and I think that what's important is stating out front exactly what is meant in the definition.”
“If you're doing a systematic review, you almost have to take the interventions as they come, and having a very elaborate formal definition of what a complex intervention is isn't likely to be helpful.”
“…just be clear about what terms you're going to use and what they mean, because there's no shared view of it.”
Comments on using the word “complex” and/or “multicomponent”
“I think actually in talking about this I've used the phrase complex multicomponent intervention.”
“…multicomponent is often the common term that's used.”
“So, my rule of thumb is if it's complex it must be multifaceted, but it's got to be more than multifaceted. So everything that's multifaceted isn't necessarily complex”; “I would turn it around and ask people in health care what's not complex. So if everything is complex then it isn't actually helpful to distinguish it as a term.”
“It's quite unusual to find a real care intervention that's not multifaceted and to some degree complex. I don't think it's (complex) essential but it certainly fits; it's appropriate from my view point.”
“I think the term multicomponent is much clearer. I know what that means”; “If you say it's a complex intervention I don't know what that means.”
“I suppose I tend to use complex interventions most commonly, but more recently, we have been talking about reviews of complex questions. So, sometimes it's the question that's complex and/or the intervention.”
“You need to distinguish between multicomponent interventions, which typically are complex, and complex interventions, which can include a number of other dimensions of complexity besides having multiple components.”

Table C-2 Frameworks

“…So we tried using PICOT, but we ended up it was sort of PICOT plus.”; “What we ended up doing was developing a conceptual framework around relevant to the intervention, and I think in both cases we ended up using the Donabedian Framework to organize our thinking.”
“Well, I like PICOT. I think that you can play with it a little bit to expand it. I agree … that it would have to be PICOT plus.”
“I think you need a framework to describe interventions (in addition to PICOT) so that people understand what the intervention is and they can replicate it.”
“Yes, I agree that (PICOT) … is a good framework. I would just add that for complex health system interventions I would also emphasize the importance of assessing not just the predicted outcomes, but also what potential unintended consequences looked for… I think one can sometimes get system wide effects which were not necessarily anticipated at the outset, unless you have a consistent and transparent way of trying to look for those unanticipated effects.”
“I think PICOT works really well. The adapt collaboration modified PICOT to PIPOH… The second P is for professionals and patients, so who are the audience that the guideline or the intervention is targeted towards, outcomes. Then, the H at the end of it is the health care setting or context. I'm not sure that it matters what that framework is if it's sufficiently broad enough to capture kind of the important issues that it would be great if everybody could report on.”
“I don't see a great alternative.”
“I think PICOT is a useful starting point.”
“The issue is how you want to operationalize it; so the first P is population, provider, process. It's about just deciding what it is. I mean it's just a mnemonic, so I don't actually buy that it doesn't fit and it's only for more pharmacological kinds of approaches. We use it all the time and even when it's not for an experimental design, we change the C from control to context and use it in qualitative studies, because it's useful to be clear about the issues. Perhaps those issues to me might be reflecting people's lack of familiarity or appreciation that in fact I think it's pretty robust. It's a matter of getting agreement on what does the C stand for? In some cases, it may be the control; and other cases, it may be the context; and maybe, it's a C squared.”
“From a policymaker standpoint you could say, ‘Gee, it looks like some of these used eight components and some used three. There's no clear relationship between the number of components and the effect. So I'm just going to use the one that's simpler and cheaper.’ That's not necessary strong evidence, but it's better than if you hadn't looked at all.”
“My own sort of subjective sense is that the less helpful approaches are ones that try to be too quantitative and try to divide up individual elements (mentions meta-regression on components). I think more effective approaches are ones that, as you say, adequately describe the context and the components in enough detail that a user could say; you know, that looks a lot like my setting.”
“The logic model basically talks about how the intervention is expected to be linked to the outcomes, like through what processes affecting what individuals, and so forth.”(referred to Lori Anderson & Julie Littell logic models)
“There is a group currently trying to develop guidance on the conduct of process evaluations, it's in the … and they are developing a schema for classifying process evaluations, and it's something that I think is primarily intended to help people conduct these things.”
“We probably don't spend enough energy on describing the comparator, actually.”
“Having some process to say, we focused on these particular questions based on input from clinicians about what things they thought were going to be the most important to them in terms of implementing these programs… I think where it gets trickiest is when you've got a multicomponent intervention that has multiple targets … (you are) wanting to know their interactions between those components.”

Table C-3 Study Design

“In most of the Effective Practice and Organisation Care work, we've limited reviews to randomized trials, controlled before or after studies, and interrupted time series. We've also included, I suppose, non-randomized trials and repeated measures, which are a variance of those. We have very little experience with other types of study designs and we're just starting, colleagues of mine, to look at ways of incorporating findings from qualitative research. They (qualitative studies) informed judgments about the applicability of the intervention and the feasibility of the intervention primarily. To some extent, they informed other judgments.”
“… it's especially a problem with smaller studies and single site studies, because what they don't account for is the enthusiasm factor. I think that's why so many of them are non-reproducible, because in fact the biggest part of the intervention was often the implementers rather than necessarily even the intervention.”
“We've all been taught pre-posts are terrible, but I think in some situations if they're carefully done they could be okay.”
“Clearly there's some case series where the case fatality rate before and after the intervention is so dramatically different that the odds that the intervention made the difference seem to be very high.”
“I certainly think the net should extend beyond randomized control trials to include well designed observational studies, and the criteria for inclusion should be based on specific characteristics of the study, not on what broad class of design they fall within.”
“Case study designs could give useful information, not so much necessarily about effect, but certainly about issues around implementability around contextual factors which might affect the uptake of particular interventions.”
“If the question is about the effectiveness of the intervention, then experimental designs are better than observational ones… If the question is around, ‘Well, what are the components? Why do they seem to work?’ Then observational qualitative kinds of designs would be the appropriate ones to help try to tease that out.”
“…say we found 400 studies and we looked at the three that were randomized trials of XXX. I just think on its face value that looks ridiculous.”
“There is a classic text though, to my mind at least, that really is talking about study design. It's called Realistic Evaluation. It's by two British statisticians, Pawson and Tilley, and what they do is criticize randomized designs. They criticize them explicitly because they lose context, and then recommend new designs where you include the context as part of your design, build it right in as part of your design… they base their what they call CMO designs, context, mechanism, outcomes designs.”
“… that we need a much better understanding of when it's useful to look for these observational studies because it's very time-consuming to do so. It adds a lot of work to the review, and if you have 35 trials and 1 controlled or after study, it's a very unlikely that the control or after study is going to make an important contribution to the findings of that review even though you've had to wade through 5,000 abstracts to find it. I think where there are trials, I'm keen to stick to them and I think we need better—more information on where it's useful to look for other things.”
“I'm also a bit ambivalent about some of the more complex designs like … difference and all of that stuff—some of those more econometric designs. There's a lot of interest in those now… but I think realistically most review authors are going to struggle to manage those kinds of data. They're very complicated to understand and to analyze in this analysis.”
Role of Qualitative Studies
“There are a whole lot of ways that qualitative evidence … can contribute. I think they could be helpful in developing better definitions on an intervention and understanding implementation considerations and understanding why interventions work or not in helping to see what outcomes are seen as important by different stakeholders.”
“We have very little experience with other types of study designs and we're just starting, colleagues of mine, to look at ways of incorporating findings from qualitative research. They (qualitative studies) informed judgments about the applicability of the intervention and the feasibility of the intervention primarily. To some extent, they informed other judgments. For process evaluations, it's often qualitative research.”
“I think the argument that's being made here is the need for mixed methods studies, so that there's a qualitative component, because we found the same thing, you miss a lot if you just solely rely on existing literature, and even just preconceived notions based on experience.”
“… qualitative evaluation, I often argue, is more important because what you want to understand is what went wrong. If you're producing negative studies on a repeated basis, you really do need those qualitative observations to understand why the study was negative.”
“I think some of the most interesting information that's come out of it has come out of qualitative discussions, focus groups, and feedback from the clinicians in the practices talking about what they liked about the intervention. What their patients liked, and also, talking about the real challenges of being a busy primary care clinician with lots of competing demands for their time and attention, but struggling to try to make something that doesn't fit within the usual—”
“I think qualitative studies can be very helpful in terms of learning about how to implement something or they can give insight into why something works or doesn't work.”

Table C-4 Analytic Considerations

Pitfalls
“So, realist synthesis is an example of that, just sort of unhelpful jargon. And then, people use several different descriptors for whatever they want to call it, the logic model, theoretical approach. There's different terms for that, but it's all pretty much just different ways of saying the same thing… then another pitfall that I think is probably the biggest problem in this area is what some reviewers, a lot of reviewers end up doing when they look at complex interventions is they just sort of wave their hands in the air and they say, ‘We're just going to do a descriptive analysis, a narrative analysis, a qualitative analysis.’ Typically what that means is they have no idea how they're going to do the analysis and they just either do vote counting and they make some inappropriate analysis based on the number of positive and negative studies, which is usually misinformative, or they just list the results of one study after another, which is essentially the same as doing a sub-group analysis for each study and isn't very helpful to people who are trying to use the review because it doesn't provide any kind of synthesis.”
“Well, we tend to look at what are the key components and then think about, of those key components which of those do you have to have a high degree of fidelity and which can be adapted to the setting and … being implemented. And then for the evaluation piece, we know that people start at different places, they move at different speeds, and the implementation is not a static kind of thing, you don't just implement and then you stay there, things can change, particularly when they're multifaceted interventions.”
“There are not agreed upon standards for what constitutes an effective implementation and there's also not good evidence in the literature for what are good, expected effects. Where you're simultaneously monitoring the implementation and then also developing the evaluation criteria and performing the evaluation almost on a rolling basis and adapting it for what you see. A lot of the effects we are starting to see are not what would have been hypothesized on the basis of literature … because even as you're doing the evaluation, much less rolling up multiple studies, I think it's hard to have a rigid, fixed set of criteria.”
“… I think we have to be eclectic, we have to look at the range of different disciplines and what they can bring to the table, use qualitative and quantitative data.”
Best Practices
“We've embraced more of a realistic evaluation approach versus a traditional evaluation approach, which does beg to the sort of formative or monitoring evaluation that morphs as you move along and learn more and you inform the team.”
“Depending on the design they used what did they do with that missing data.”
“… get the unit of analysis coordinated with the unit of assignment.”
“… but it needs to be analyzed correctly statistically to take into account the clustering, otherwise things look statistically significant that really are not.”
“… you have an obligation, Harris Cooper might say it's almost an ethical obligation, to provide the most rigorous possible synthesis under the circumstances.”
“A systematic review of a complex intervention is useful is that the reviewer has imposed an adequate amount of structure on the data to maximize its utility, that basically when you have a heterogeneous set of evidence, it's really incumbent on the reviewer to impose an amount of structure on it that allows a lumping of the maximum amount of information together that is reasonably similar, while excluding information that is an outlier and is just going to muddy the water.”
“One aspect of that (translating systematic review to guidance) is the way effect estimates are presented … some of them are translated into terms that are readily understandable by non-statisticians in natural terms such as numbers needed to treat, rather than … ratios.”
“I think there are also some methods that can probably be borrowed from other disciplines, like, for example, econometricians seem to have some interesting methods which we haven't used very much in health, regression discontinuity designs and so on, which we're not very familiar with in the health sector, but could potentially be useful.”
“A big question from our, that we … grappling with this review is when does it make sense to pull data to do a meta-analysis and when not to, and obviously it's a judgment about the sort of level of clinical heterogeneity, what I call intervention heterogeneity as well as looking at other more statistical measures.”
“Oftentimes, it's useful to consult with people who work closely in the field with those types of interventions, they often have a view on how similar or different it is, but what they base that on.”
“We, for example, are developing now an interactive summary of findings table that we think will be helpful for people who try to get to grips with the statistical information included in reviews.”