# Key Informants

- David Atkins, M.D., M.P.H.
  Director of Quality Enhancement Research Initiative
  Department of Veterans Affairs
  Washington, DC
- Peter Craig, Ph.D., M.S.
  Medical Research Council, Population Health Sciences Research Network
  Scottish Executive Health Department
  Glasgow, UK
- Randy Elder, Ph.D., M.Ed.
  Scientific Director of Systematic Reviews
  CDC Guide to Community Preventive Services
  Atlanta, GA
- Stephan Fihn, M.D., M.P.H.
  Director of the Office of Analytics and Business Intelligence
  Department of Veterans Affairs Puget Sound Health Care System
  Seattle, WA
- Ian Graham, Ph.D., FCAHS
  Senior Scientist, Clinical Epidemiology
  Ottawa Hospital Research Institute
  Ottawa, ON
- David Grossman, M.D., M.P.H.
  U.S. Preventive Services Task Force
  Seattle, WA
- Sir Andy Haines, M.B.B.S., M.D.,
  FRCGP, FFPHM, FRCP, F.Med.Sci.
  Professor of Public Health and Primary Care
  Department of Social and Environmental Research and Department of Population Health
  London School of Hygiene and Tropical Medicine
  London, UK
- Brent James, M.D., M.Stat.
  Executive Director
  Intermountain Institute for Health Care Delivery Research
  Salt Lake City, UT
- Simon Lewin, M.B.B.Ch., Ph.D.
  Senior Researcher, Global Health Unit
  Norwegian Knowledge Center for the Health Services
  Oslo, Norway
- Andy Oxman, M.D.
  Researcher, Global Health Unit
  Norwegian Knowledge Center for the Health Services
  Oslo, Norway
- Debbie Peikes, Ph.D., M.P.A.
  Senior Fellow
  Mathematica Policy Research
  Princeton, NJ
- Eugene Rich, M.D.
  Senior Fellow
  Mathematica Policy Research
  Washington, DC
- Hannah Rothstein, Ph.D., M.A.
  Professor of Management, Baruch College
  Zicklin School of Business
  New York, NY
- Lucy Savitz, Ph.D.
  Director of Research and Education
  Intermountain Institute for Health Care Delivery and Research
  Salt Lake City, UT
- Jonathan Tobin, Ph.D.
  President, Clinical Directors Network
  Bronx, NY