# Search Strategy

Database searched
- Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to February Week 2 2013
- Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations February 11, 2013

Date searched: February 11, 2013

1 | exp medical assistance/ | 46902
2 | exp regional health planning/ | 35049
3 | exp hospitals/ | 189283
4 | health services administration/ | 3848
5 | hospital administration/ | 27563
6 | exp managed care programs/ | 38311
7 | (HMO or managed care or hospital* or ((health* or medic* or state or federal) adj3 (service* or system* or administrat* or manag* or program*))).ti,ab. | 990637
8 | exp health services research/ | 112596
9 | health plan implementation/ | 3339
10 | exp Medical Errors/ | 78075
11 | Reimbursement, Incentive/ | 2708
12 | exp hospital information systems/ | 24915
13 | exp management information systems/ | 36856
14 | exp Medical Records/ | 78315
15 | exp Quality Improvement/ | 2667
16 | exp “Quality of Health Care”/ | 4501047
17 | exp Quality Assurance, Health Care/ | 237068
18 | exp Quality Indicators, Health Care/ | 11052
19 | exp Quality Control/ | 38203
20 | exp Patient Care Management/ | 490688
21 | exp health services/ | 1463466
22 | exp mass screening/ | 92929
23 | (error* or pay for performance or incentiv* or screening or vaccination or immuni?ation or quality or records or knowledge transfer or implement* or intervention* or patient).ti,ab. | 2798834
24 | ((intervention$ or treatment$ or component$ or parameter$) adj2 (multiple or complex or mixed or multi faceted or multifaceted or multi parameter or multiparameter or multi component or multicomponent)).ti,ab. | 30816
25 | (methodol$ or review$ or meta anal$ or metaanal$ or cluster randomized or interrupted time series or concurrent control or historic control).ti,ab. | 1296626
26 | or/1-7 | 1143956
27 | or/8-23 | 6823256
28 | 24 and 25 and 26 and 27 | 678
29 | limit 28 to english language | 635
30 | remove duplicates from 29 | 628

Database searched
- Ovid EBM Reviews-Cochrane Database of Systematic Reviews 2005 to November 2012

Date searched: January 11, 2013

| Search | Results
1 | ((intervention$ or treatment$ or component$ or parameter$) adj2 (multiple or complex or mixed or multi-faceted or multifaceted or multi parameter or multiparameter or multi component or multicomponent)).ti,ab. | 134

Database searched
- Ovid EBM Reviews-Cochrane Methodology Register 3rd Quarter 2012

Date searched: January 11, 2013

| Search | Results
1 | ((intervention$ or treatment$ or component$ or parameter$) adj2 (multiple or complex or mixed or multi faceted or multifaceted or multi parameter or multiparameter or multi component or multicomponent)).ti,ab. | 137