# References

1 McDonald KM, Chang C, Schultz E. Closing the Quality Gap: Revisiting the State of the Science. Summary Report. (Prepared by Stanford-UCSF Evidence-based Practice Center under Contract No. 290-2007-10062-I.) AHRQ Publication No. 12(13)-E017. Rockville, MD. Agency for Healthcare Research and Quality. January. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Institute of Medicine. Best Care at Lower Cost: The Path to Continuously Learning Health Care in America. Washington, DC. The National Academies Press. 2012.
3 Mangione-Smith R, DeCristofaro AH, Setodji CM, et al. The quality of ambulatory care delivered to children in the United States. N Engl J Med. Oct. 11. 2007;357(15):1515-23. [pmid: 17928599].
4 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. Jun. 26. 2003;348(26):2635-45. [pmid: 12826639].
5 Committee on Identifying Priority Areas for Quality Improvement. Priority Areas for National Action: Transforming Health Care Quality. Washington, DC. The National Academies Press. 2003.
6 Committee on Quality Health Care in America, Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC. The National Academies Press. 2001.
7 Chassin MR, Loeb JM. The ongoing quality improvement journey: next stop, high reliability. Health Aff. 2011;30(4):559-68. [pmid: 21471473].
8 Shojania KG, McDonald KM, Wachter RM, et al. Series Overview and Methodology. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04-0051-1. Rockville, MD. Agency for Healthcare Research and Quality. 2004;1. www.ncbi.nlm.nih.gov/books/NBK43908/.
9 Luce JM, Bindman AB, Lee PR. A brief history of health care quality assessment and improvement in the United States. West J Med. Mar. 1994;160(3):263-8. [pmid: 8191769].
10 Donabedian A. Evaluating the quality of medical care. 1966. Milbank Q. 2005;83(4):691-729. [pmid: 16279964].
11 McDonald KM, Graham ID, Grimshaw J. Toward a theoretic basis for quality improvement interventions. In: Shojania KG, McDonald KM, Wachter RM, et al. Series Overview and Methodology. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04-0051-1. Rockville, MD. Agency for Healthcare Research and Quality. 2004;1. chapter 3. www.ncbi.nlm.nih.gov/books/NBK43908/.
12 Ovretveit J. The contribution of new social science research to patient safety. Soc Sci Med. Dec. 2009;69(12):1780-3. [pmid: 19853338].
13 Berwick DM. Controlling variation in health care: a consultation from Walter Shewhart. Med Care. 1991;29(12):1212-25. [pmid: 1745079].
14 Deming W. Out of the Crisis: Quality, Productivity and Competitive Position. New York. Cambridge University Press. 1982.
15 Juran JM. Juran on Planning for Quality. New York. Free Press. 1988.
16 Juran JM, Gryna FM. Juran's Quality Control Handbook. New York. McGraw-Hill. 1988.
17 Perneger TV. The Swiss cheese model of safety incidents: are there holes in the metaphor?. BMC Health Serv Res. 2005;5:71. [pmid: 16280077].
18 Reason J. Human error: models and management. BMJ. Mar. 18. 2000;320(7237):768-70. [pmid: 10720363].
19 Kohn K, Corrigan J, Donaldson MS. To Err Is Human: Building a Safer Health System. Washington, DC. Institute of Medicine. 1999.
20 Desai V, Madsen PM, Roberts KM. High-reliability organizations in health care In: Handbook of Human Factors and Ergonomics in Health Care and Patient Safety. 2nd ed. CRC Press. 2011:173-84. chapter 12.
21 Proctor EK, Landsverk J, Aarons G, et al. Implementation research in mental health services: an emerging science with conceptual, methodological, and training challenges. Adm Policy Ment Health. Jan. 2009;36(1):24-34. [pmid: 19104929].
22 Greenhalgh T, Robert G, Macfarlane F, et al. Diffusion of innovations in service organizations: systematic review and recommendations. Milbank Q. 2004;82(4):581-629. [pmid: 15595944].
23 Bowman CC, Sobo EJ, Asch SM, et al. Measuring persistence of implementation: QUERI Series. Implement Sci. 2008;3:21. [pmid: 18430200].
24 Voorn VM, de Mheen PJ, So-Osman C, et al. Designing a strategy to implement cost-effective blood transfusion management in elective hip and knee arthroplasties: a study protocol. Implement Sci. 2012;7(1):58. [pmid: 22747693].
25 Ovretveit J. Improvement leaders: what do they and should they do? A summary of a review of research. Qual Saf Health Care. Dec. 2010;19(6):490-2. [pmid: 21127110].
26 Bravata DM, Sundaram V, Lewis R, et al. Asthma Care. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04(07)-0051-5. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007;5. http://purl.access.gpo.gov/GPO/LPS81286.
27 McDonald K, Sundaram V, Bravata D, et al. Care Coordination. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under contract 290-02-0017). AHRQ Publication No. 04(07)-0051-7. Rockville, MD. Agency for Healthcare Research and Quality. June. 2007;7.
28 Ranji SR, Shetty K, Posley KA, et al. Prevention of Healthcare-Associated Infections. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04(07)-0051-6. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007;6. www.ncbi.nlm.nih.gov/pubmed/20734530.
29 Ranji S, Steinman M, Shojania K, et al. Antibiotic Prescribing Behavior. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04(06)-0051-4. Rockville, MD. Agency for Healthcare Research and Quality. January. 2006;4.
30 Walsh J, Sundaram V, Nayak S, et al. Hypertension Care. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04-0051-3. Rockville, MD. Agency for Healthcare Research and Quality. January. 2005;3.
31 Shojania KG, Ranji S, Shaw L, et al. Diabetes Mellitus Care. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04-0051-2. Rockville, MD. Agency for Healthcare Research and Quality. September. 2004;2.
32 The Commonwealth Fund. Timeline for Health Care Reform Implementation: System and Delivery Reform Provisions. 2012. http://mobile.commonwealthfund.org/∼/media/Files/Publications/Other/2010/Timeline%20System%20Reform_040110_v5_rev%2051310.pdf. August 21, 2012.
33 Hussey PS, Mulcahy AW, Schnyer C, et al. Bundled Payment: Effects on Health Care Spending and Quality. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the RAND Evidence-based Practice Center under Contract No 290-2007-10062-I.) AHRQ Publication No. 12-E007-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
34 Williams JW, Jackson GL, Powers BJ, et al. The Patient-Centered Medical Home. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Duke Evidence-based Practice Center under Contract No 290-2007-10066-I.) AHRQ Publication No. 12-E008-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
35 McPheeters ML, Kripalani S, Peterson NB, et al. Quality Improvement Interventions To Address Health Disparities. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Vanderbilt University Evidence-based Practice Center under Contract No. 290-2007-10065.) AHRQ Publication No. 12-E009-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
36 Viswanathan M, Golin CE, Jones CD, et al. Medication Adherence Interventions: Comparative Effectiveness. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-E010-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
37 Totten AM, Wagner J, Tiwari A, et al. Public Reporting as a Quality Improvement Strategy. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 12-E011-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
38 Mauger Rothenberg B, Marbella A, Pines E, et al. Prevention of Healthcare-Associated Infections. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058.) AHRQ Publication No. 12(13)-E012-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
39 Butler M, Kane RL, Larson S, et al. Quality Improvement Measurement of Outcomes for People With Disabilities. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Pubication No. 12(13)-E013-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
40 Dy SM, Aslakson R, Wilson RF, et al. Improving Health Care and Palliative Care for Advanced and Serious Illness. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report No. 208. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 12(13)-E014-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
41 Department of Health and Human Services. Report to Congress: National Strategy for Quality Improvement in Health Care. March. 2011. www.healthcare.gov/law/resources/reports/quality03212011a.html#top.
42 Patient Protection and Affordable Care Act. Public Law No. 111-148. 2010.
43 Fuchs VR. The proposed government health insurance company--no substitute for real reform. N Engl J Med. May. 28. 2009;360(22):2273-5. [pmid: 19474424].
44 Iezzoni LI. Eliminating health and health care disparities among the growing population of people with disabilities. Health Aff (Millwood). Oct. 2011;30(10):1947-54. [pmid: 21976339].
45 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2011. Chapters available at www.effectivehealthcare.ahrq.gov. July 26, 2012.
46 Agency for Healthcare Research and Quality. The Refinement of Topics for Systematic Reviews: Lessons and Recommendations from the Effective Health Care Program [Draft Report]. 2012. www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=1188. October 19, 2012.
47 Adams Dudley R, Frolich A, Robinowitz DL, et al. Strategies To Support Quality-Based Purchasing: A Review of the Evidence. Technical Review 10. (Prepared by the Stanford-University of California San Francisco Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04-0057. Rockville, MD. Agency for Healthcare Research and Quality. July. 2004. www.ncbi.nlm.nih.gov/books/NBK43997/.
48 Shekelle P, Pronovost P, Wachter R, et al. Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices: Developing Criteria. (Prepared under Contract No. HHSA-290-2009-10001C.) AHRQ Publication No. 11-0006-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2010.
49 Foy R, Ovretveit J, Shekelle PG, et al. The role of theory in research to develop and evaluate the implementation of patient safety practices. BMJ Qual Saf. May. 2011;20(5):453-9. [pmid: 21317181].
50 Shekelle PG, Pronovost PJ, Wachter RM, et al. Advancing the science of patient safety. Ann Intern Med. May. 17. 2011;154(10):693-6. [pmid: 21576538].
51 Ovretveit JC, Shekelle PG, Dy SM, et al. How does context affect interventions to improve patient safety? An assessment of evidence from studies of five patient safety practices and proposals for research. BMJ Qual Saf. Jul. 2011;20(7):604-10. [pmid: 21493589].
52 Office for Human Research Protections. OHRP Correspondence, Department of Health and Human Services. 2008. www.hhs.gov/ohrp/policy/Correspondence/pronovost20080730letter.html. September 12, 2012.
53 Office for Human Research Protections. Quality Improvement Activities: Frequently Asked Questions. Department of Health and Human Services. 2011. www.hhs.gov/ohrp/policy/qualityfaqsmar2011.pdf. September 12, 2012.
54 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
55 Agency for Healthcare Research and Quality. Children's Health Insurance Program Reauthorization Act (CHIPRA) Children's Health Care Quality Measurement and Improvement Activities. 2012. www.ahrq.gov/chipra/index.html#Core. September 12, 2012.
56 Agency for Healthcare Research and Quality. National Advisory Council Subcommittee: Identifying Health Care Quality Measures for Medicaid-Eligible Adults, Background Report. 2011. www.ahrq.gov/about/nacqm11/index.html#Contents. September 12, 2012.
57 U.S. Department of Health and Human Services. Center of Excellence in Research on Disability Services Care Coordination and Integration. 2010. www.hhs.gov/news/press/2010pres/05/20100506a.html. September 24, 2012.
58 McDonald KM, Schultz E, Pineda N, et al. Care Coordination Accountability Measures for Primary Care Practice. (Prepared by Stanford University under subcontract to Battelle on Contract No. 290-04-0020.) AHRQ Publication No. 12-0019-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2012.
59 Davidoff F, Batalden P, Stevens D, et al. Publication guidelines for quality improvement in health care: evolution of the SQUIRE project. Qual Saf Health Care. Oct. 2008;17(Suppl 1):i3-9. [pmid: 18836063].
60 de Bruin M, Viechtbauer W, Schaalma HP, et al. Standard care impact on effects of highly active antiretroviral therapy adherence interventions: a meta-analysis of randomized controlled trials. Arch Intern Med. Feb. 8. 2010;170(3):240-50. [pmid: 20142568].
61 The Cochrane Collaboration. Cochrane Effective Practice and Organisation of Care Group. 2012. http://epoc.cochrane.org/. September 24, 2012.
62 Ovretveit J, Gustafson D. Evaluation of quality improvement programmes. Qual Saf Health Care. Sep. 2002;11(3):270-5. [pmid: 12486994].
63 Alexander JA, Hearld LR. Methods and metrics challenges of delivery-system research. Implement Sci. 2012;7:15. [pmid: 22409885].
64 Damschroder LJ, Aron DC, Keith RE, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4:50. [pmid: 19664226].