# Quality Improvement: Next Steps in an Evolving Field

The Closing the Quality Gap series offers insight about challenges—and potential solutions—in performing systematic reviews of complex quality improvement (QI) interventions by including diverse topics that address each of the three main levers for improving quality (information, incentives, and infrastructure). In addition, this series provides a window into the “state of the science” for the field of QI research. In this chapter, we discuss five current challenges facing the QI research community that are apparent from review of the eight series topic reports and propose steps that may help advance this rapidly evolving field. Some of these insights echo those aimed at future systematic reviews, but apply especially to primary research studies and the practical needs of those working to improve quality.

## Advancing the Field Through Evidence Synthesis

Many topics included in this series are at early stages of scientific exploration, and theories about the mechanisms through which QI initiatives lead to improvements are still evolving. For example, the patient-centered medical home (PCMH) review focused on one particular model for care delivery—the patient-centered medical home—and found that many investigations exploring the effectiveness of the model overall and its various component parts are just getting underway. Those studies that have already been published vary greatly in their implementation of PCMH components, underscoring the still-evolving nature of the PCMH model. The topic team estimated that the amount of evidence relating to the effectiveness of PCMH as a delivery model will more than double in the next few years. Both the Disability Outcomes and Disparities teams also found an evidence base that is early in its development. The Palliative Care team found that theoretical underpinnings for improvement strategies targeted at patients with advanced and serious illness were frequently lacking and suggested that future improvement efforts incorporate theory from the QI field. Authors of the Bundled Payment report found that implementations of this payment model are shifting from predominantly single-setting designs to more complex multiple-setting initiatives, but that the literature base on bundled payment has not yet caught up to this shift.

Although reviewing the literature related to topics in an early stage of theoretical and evidentiary development can yield only preliminary evidence, it will help to improve the quality of future evidence by identifying knowledge gaps, providing an organizing framework for subsequent reviews, and suggesting best practices for future evaluations. Ultimately, the aim is to guide further primary research and enable future evidence synthesis that will be able to address, not just whether particular improvement models are or are not effective, but why and under what circumstances they are effective. Addressing those questions will require further development of theoretical models that concern mechanisms for achieving systems change.

Other reports in this series, in particular Public Reporting, healthcare-acquired infections (HAI), and Medication Adherence, addressed “hot topics” with a more established body of literature but for which many combinations and permutations of improvement approaches have been tried, such that there are often only one or two studies of the same approach. For such topics, systematic reviews contribute to hypothesis generation about components to test together or singly as the theory and implementable solutions evolve through further well-directed research. Including some information from qualitative research within reviews, as the Public Reporting reviewers did, can also contribute to hypothesis generation and development of change theory. For example, information from patient interviews and focus groups identified shortcomings in many current public reporting initiatives that limited their usefulness to consumers. This qualitative evidence suggested aspects of public reports that should be evaluated in future investigations, and also hinted at how and why consumers might use publicly reported information for making particular health care decisions. In this way, the review suggested avenues for further exploration of the role of consumer behavior in improvement efforts, in addition to the primary objective of synthesizing evidence about the effectiveness of various public reporting initiatives.

## The Challenge of Measurement

All eight reviews in this series were limited in their ability to synthesize the available evidence and draw conclusions across studies, in part by the extreme heterogeneity in outcomes measured. Studies varied widely, not just in the choice of specific outcomes reported but also in how those outcomes were measured. For example, medication adherence was, by definition, an outcome in all studies included in that topic review, but synthesis was hampered by the great variability in how medication adherence was defined across studies. The Palliative Care review found a wide variety of outcomes reported across studies, including pain, symptoms, distress, patient and family satisfaction, quality of life, and health care utilization. A number of these outcomes are patient centered and therefore aligned well with quality concepts. However, this heterogeneity, along with broad differences in interventions and study designs, limited the review authors' ability to draw conclusions across studies and to quantitatively assess the strength of evidence. They also noted that many studies reported multiple outcomes but rarely designated a single primary outcome as the focus of the study, diluting assessments of intervention effectiveness.

Across all topics, we see the need for more coordinated efforts at measure development. While much of the current research includes commonly measured outcomes such as patient satisfaction, health care utilization, and quality of life, variability across studies in how these concepts are defined, as well as which of these common outcomes are reported in particular studies, continues to limit comparative synthesis. More consistent use of particular outcomes—those most pertinent to a particular topic—would better facilitate comparative synthesis across studies. The experience of this series suggests that QI research would greatly benefit from efforts to develop a core set of clearly defined and fully specified outcomes measures. Some such efforts are underway, such as development of a core set of children's health care quality measures for use by Medicaid and the Children's Health Insurance Program,55 development of a set of measures for use in Medicaid-eligible adults,56 and prioritization of outcomes in comparative effectiveness research on services and care coordination for people with disabilities.57 These proposed sets include a mix of process and outcomes measures; outcomes typically relate to health care utilization (emergency department visits, hospitalizations, and readmissions) but also include some measures of patient experience. Efforts to harmonize measurement for other commonly used outcomes, such as quality of life, would further benefit the field. Consensus-based measures of economic outcomes are also particularly needed. Less commonly reported in QI research, but also important, are measures applicable to the equity dimension of quality and therefore applicable to disparity reduction. The reports in the series may offer a starting point for consensus development, or at a minimum, provide a one-stop shop to see which previous measures have been used more frequently in primary studies of these topics.

In addition to outcomes that apply across a broad range of patient populations, care processes, and systems, particular areas with a large number of research studies, such as PCMH and medication adherence, would further benefit from a topic-specific core measure set. Recently, the Agency for Healthcare Research and Quality led efforts to develop a core set of process measures for care coordination, another complex context-dependent topic related to QI via infrastructure.58 The resulting measure set is limited by weaknesses in the underlying measures. Only existing measures were considered; no new measure development was undertaken. However, this preliminary effort demonstrates how even a provisional measure set can provide a starting place for more consistent measurement while efforts to develop new measures or refine existing ones are underway. The care coordination measurement effort began with a systematic review and environmental scan of available measures similar to the Disability Outcomes review included in this series. The Disability Outcomes review and other series reports (e.g., Palliative Care, Medication Adherence, PCMH) even included aspects of care coordination in their scope. Similar efforts to review and evaluate outcomes measures for wide application in QI research could benefit the field.

While including at least one of a core set of outcomes would greatly facilitate comparative synthesis across studies, use of standardized measures from a core measure set must be balanced with the need to tailor outcomes measures to the research questions and goals of particular QI efforts or research studies. Across series topics, results were often mixed for different outcomes evaluated. This was particularly true for the Bundled Payment review, which found that both the magnitude and direction of effects varied within and across studies that used different quality measures. Likewise, the Palliative Care review found that many interventions improved some, but not all, outcomes measured, and the Medication Adherence review found that only a subset of the interventions that improved adherence also improved other outcomes.

These results underscore the importance of selecting outcomes measures that closely match intervention goals for researchers. Choice of outcomes should also include consideration of the many different stakeholders involved in care, while staying centered on the needs and values of the population under study. The authors of the Disability Outcomes review especially emphasized this point, noting that the professional perspective of study leaders (e.g., medicine, rehabilitation, social support) tended to influence the choice of outcomes in disability research, with important implications for whether a particular intervention was shown to be effective. They cautioned that choice of outcomes can contribute to health care disparities if the outcomes are not aligned with the values and needs of the population under study. If developed, a core set of outcomes measures for use in QI research should include input from a wide range of stakeholders, cover a broad scope of potential outcomes of interest, and serve as a set of standardized options from which researchers can select individual measures as needed.

## Improving Study Quality

Across all eight series topics, study quality was modest at best. Only a handful of individual studies were rated as high quality (with minimal risk of bias), and among all eight reports, only two conclusions, both related to contextual factors impacting effectiveness of public reporting, were based on high strength of evidence. The HAI review found that the quality of studies had increased between the previous review in 2007 and the update for this series, but overall quality still had ample room for improvement. All of the reports that evaluated interventions (excluding Disability Outcomes) noted a need for more rigorous study designs within their topic areas (Table 4), including greater use of randomized controlled trials (HAI) or quasi-experimental or natural experiment designs (Bundled Payment, PCMH, HAI); use of appropriate comparison groups (Bundled Payment, Disparities); incorporating multiple preintervention and postintervention measurements into before-after studies; and, when possible, conducting interrupted time series analyses (Bundled Payment, HAI); using longer followup periods (Bundled Payment, HAI, PCMH, Medication Adherence); increasing sample sizes and participant retention (Palliative Care); controlling for confounding factors (Bundled Payment, Public Reporting, HAI); and adjusting for clustering of patients within providers, clinics, hospitals, or other health care delivery organization units (PCMH) (Table 4). Other recommendations to advance the state of the science are discussed below under Consistent and Complete Reporting.

Table 4 Recommendations for improving the quality of evidence across Closing the Quality Gap series topics

Topic | Use More Rigorous Study Designs | Investigate Harms | Report/Examine Context | Report/Examine Intervention Features | Study Additional Subgroups
Bundled Payment | ■ | ■ | ■ | ■ | ■
PCMH | ■ | ■ | | ■ | ■
Disparities | ■ | ■ | | | ■
Medication Adherence | ■ | ■ | | ■ | ■
Public Reporting | ■ | | ■ | ■
HAI | ■ | | ■
Disability Outcomes | N/A | N/A | N/A | N/A | N/A
Palliative Care | ■ | | ■ | ■ | ■

HAI = healthcare-associated infections; N/A = not applicable; PCMH = patient-centered medical home

Note:

■ = Recommended in this topic report.

Overall, the low to moderate strength of evidence found across the eight series reports speaks to the immaturity of the QI and implementation science fields, where standards for robust study design continue to evolve. The authors of the HAI report noted that, although randomized controlled trials are considered the gold standard for demonstrating efficacy of medical treatments, they may be less applicable to QI research, where complex context-dependent interventions are typically applied at a system level rather than at the level of the individual patient or provider. Similarly, the authors of the Public Reporting review suggested that further methodologic research is needed to adapt the tools of comparative effectiveness research from the clinical research domain, where they were developed, to the QI and health services research domains. The experiences of all eight topic teams for this series support both these recommendations and echo many others in the somewhat overlapping patient safety, QI, and implementation fields. An additional weakness ripe for further methodologic development is achieving sufficient statistical power with relatively few intervention units (e.g., hospitals, clinics, health systems) for organization-level interventions.

While calling for continued improvement in study quality, we also acknowledge that a tension exists between calls for more research, better study designs, and more detailed reporting of primary studies and recognizing the inherent challenges of developing robust, thorough, and abiding insight about complex interventions.

## Consistent and Complete Reporting

A common challenge across the evidence reports was uneven reporting of important aspects of the primary studies, such as descriptions of how the study was conducted, interventions, and comparators. This presented challenges in assessing study quality and categorizing interventions. Journal space is often limited, and authors make different choices about what to report. Applicable reporting guidelines, such as Standards for Quality Improvement Reporting Excellence (SQUIRE),59 are followed by an increasing number of journals. Such incentives for more standardized reporting often provide an important foundation for the development of quality assessment tools.

Other recommendations to advance the state of the science for the series topics included systematically reporting potential harms from QI interventions; studying additional patient subgroups, in particular vulnerable populations at risk for health disparities; and more thoroughly reporting and examining the impact of context and intervention features on effectiveness (discussed below). In addition, reporting the theoretical basis or use of models in the development and description of interventions may assist with synthesis. Reporting such information will improve our understanding of the effectiveness and applicability of interventions under various circumstances.

## Health Care as a Means to Health

Ultimately, efforts to improve the quality of health care aim to improve health; the importance of generating evidence about patient-centered outcomes cannot be overstated. While all topic reports in the Closing the Quality Gap series included patient-centered outcomes, many identified gaps in the evidence. When reported, clinical outcomes were generally short term, limiting reviewers' ability to comment on sustainability and long-term improvements in health. More often, intermediate outcomes and process outcomes were reported. The topic reports noted instances in which the lack of evidence about the association between intermediate and clinical outcomes limited conclusions.

Influences on health go beyond health care. While the focus of this series is on health care quality, many reports in the series noted the importance of examining contextual factors in future research. Viewing health care within a broader context may inform future efforts in developing and implementing interventions. Generating evidence to improve our understanding of the relationships among intermediate outcomes, clinical outcomes, and other health influences, such as social context and environment, will improve our understanding of how to better intervene to improve health.

## Understanding Context

The evidence base is growing about the importance of context for quality and patient safety topics,48-51 yet all three series reports that examined the role of context (Table 3)—Bundled Payment, Public Reporting, HAI—found that information on contextual factors was often lacking, incompletely described, or noted only anecdotally. Often implementers want details about the QI environment in which studies are done (e.g., presence of six sigma or lean techniques at a hospital where a provider education strategy is tested), but this information may not be reported in the primary study. Few studies explicitly investigated interactions between context and interventions during QI implementation. The authors of four topic reports recommended that contextual factors be more frequently and robustly measured and reported (Table 4). This recommendation can be applied beyond these particular topics to other areas of QI research.50 Measuring context, combined with reporting greater detail about interventions (discussed below), would help to pry open the black box of QI implementation, yielding knowledge about which components of interventions are effective under what contexts and in modifying which outcomes. Studies designed specifically to investigate how interactions among intervention features and context affect care delivery processes and outcomes would provide information to help guide selection and design of interventions appropriate to particular settings, patient populations, and organizations. Additionally, the interaction underscores the importance of logic models to interpret and link the findings from primary studies to more systematically build the evidence base for a topic. Such studies will be dependent on reliable and valid measures of contextual factors.

Although this series did not directly address measurement of QI implementation context, the sparse evidence relating to context found in the series reviews and other sources suggests that much measure development will be needed before a core set of context measures can be identified.48-51 At this early stage of exploration, little is known about which contextual factors are important to measure and how to do so. Thus, filling this knowledge gap will require iterative measure development, measurement, research, and measure refinement. Each of these steps will contribute valuable knowledge to the field of QI research.

## Adopting a Common QI Intervention Lexicon

Teams for five series topics sought to examine QI intervention features that influence effectiveness (Table 3). All five reported that descriptions of interventions were often incomplete and lacked a common language for describing intervention features, and recommended more complete descriptions of interventions (Table 4), including key features, in order to strengthen the evidence base for their topic. All of these reports commented on the difficulty in synthesizing evidence across studies given the variability in how interventions are described. The topic teams themselves varied in how they defined intervention features. Three of the five reports that examined intervention features used categories narrowly focused to their topic, such as components of care bundles (Bundled Payment); report acceptability or accessibility (Public Reporting); and incorporation of team-based care, coordinated care, or a sustained partnership (PCMH). In contrast, the Medication Adherence and Palliative Care reviews used a much more broadly applicable framework, with Medication Adherence describing interventions with respect to their target, agent, mode, intensity, duration, and components, and Palliative Care creating a de novo framework for sorting interventions. Medication Adherence investigators further described the components using a previously developed taxonomy of 16 strategies, such as use of knowledge, attitudes, facilitation, organizational learning, and clinical champions.60 For the purposes of this series methods report and companion summary report, we have used a taxonomy of intervention types developed for the original Closing the Quality Gap series (Appendix D).8 Using this taxonomy enabled us to synthesize evidence about the effectiveness of interventions across topics, as is done in Table 2. However, although it is useful for this series and similar to approaches used for Cochrane Effective Practices and Organization of Care (EPOC) reviews,61 this taxonomy is fairly generic and leaves out details required for more nuanced analysis and insight.

This diversity in how interventions were categorized within the series partially reflects differences in the topics' scope and Key Questions but also points to the need for an underlying framework to describe QI interventions, one that would yield a common lexicon for describing interventions within the research literature. While a framework and terminology must be flexible enough to cover the diverse universe of QI strategies, consistent use of a common set of terms would help facilitate synthesis of results across studies. A common framework and lexicon for describing contexts would also help advance the field. The taxonomy of intervention types used in this methods report (and developed for the original Closing the Quality Gap series), together with additional elements from topic reviews, may provide a useful starting place for developing a consensus-based framework and lexicon.