# Introduction to the Series Development

## Problem and Motivation for Series

Despite the significant resources devoted toward health care, high-quality high-value care in the United States remains elusive, with half of patients, on average, receiving suboptimal care.2-4 Yet quality is improvable.5,6

The challenge in achieving quality is conceptual as well as practical. Although most patients have an intuitive sense of what constitutes high-quality care, quality is complex conceptually because it must encompass many different attributes and perspectives (e.g., patient, family, provider, health system, society). The Institute of Medicine (IOM) defined six key dimensions of high-quality care: that it be safe, effective, patient centered, timely, efficient, and equitable.6 In practical terms, the health care system consists of complex interrelations among people (patients, their caregivers, and providers); organizations (clinics, hospitals, insurers, payers, etc.); technologies (pharmaceuticals, devices, imaging, etc.); and processes (diagnostic workups, treatments, procedures, admissions, discharges, visits, referrals, surveillance, etc.). While challenging to study, these systems must be understood in order to guide effective improvement efforts.

Medical science studies the human body system carefully to understand biologic cause and effect, with the aim of curing or ameliorating illness. Similarly, social science applied to health systems studies the complex web of health services to understand interactions and behaviors, with the aim of improving policy and practice in ways that translate into better health for a society's population. A key question in both medical and health services science concerns the ways that altering one part of a system—either the human body or the health system—produces desired results. The pursuit of better health and health care quality challenges the research field to bridge the gap between medical thinking and social science thinking.

This combined science for improving quality started with early data-driven health care professionals (Semmelweis, Nightingale, Codman)7-9 and built further with conceptual developments for quality measurement (i.e., Donabedian's structure, process, and outcome framework).10 Accompanying a focus on measurement, the science of intervention has its own set of potentially applicable theories of behavior change and diffusion of knowledge.11,12 Intentionally building quality into the health system gained momentum with tools and principles adapted from manufacturing practice (e.g., Shewhart's statistical process control charts, Juran's Total Quality Management, Demings' Continuous Quality Improvement).13-16 Subsequently, attention expanded to patient safety and high reliability organization (“HRO”) thinking,17-20 then broadened to “implementation science” and “service innovation,”21,22 including recent concepts of “deimplementation” (removing what is no longer effective practice and organization)23,24 and improvement leadership methods.25 This short synopsis of scientific thinking highlights evidence domains pertinent to improving quality—people working to improve quality, data/measurement, evaluation tools, theories/frameworks, interventions, time effects—that weave through this report,.

With such an important aim (high-quality health care) and with such a complex target (the health care system), the series offers the expertise of systematic reviewers of the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Centers (EPCs), who have gathered and synthesized what is known and what remains to be understood across a range of health care quality topics. This report describes the approach undergirding the series and extends the individual topic-level analysis, viewing the evidence through the multiple lenses of the eight series topics, key stakeholder perspectives (patients, clinicians, health care delivery organizations, and policymakers), and three key quality levers (information, incentives, and infrastructure). Like a kaleidoscope that creates new images through multiple reflections, viewing the quality improvement (QI) field across topics and through multiple perspectives provides a novel view, highlighting complexity and revealing patterns that emerge only through cross-topic synthesis. This report aims to serve as that kaleidoscope, ultimately providing guidance for the future of QI science and practice.

## Context: Previous Series

Following an IOM study in 2003 that identified high-priority QI opportunities,5 AHRQ in 2004 launched a collection of evidence reports to guide QI efforts targeting those areas. Culminating in 2007, that series—Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies—summarized evidence about QI strategies related to diabetes, asthma, hypertension, prevention of healthcare-associated infections, antibiotic prescribing behavior, and care coordination.8,26-31

Like its predecessor, this new Closing the Quality Gap series aims to assemble the evidence about effective strategies to close the “quality gap” between what is known to be high-quality evidence-based care and what patients experience on a day-to-day basis. This series not only expands the topic terrain beyond that covered in the initial collection, but also marshals the knowledge of eight EPCs, with the goal of applying and advancing the state of the science for improving the health care system for the benefit of all patients.

## Closing the Quality Gap Series Response to the Problem

Both the previous and current Closing the Quality Gap series are intended to inform multiple audiences and serve multiple uses. For example, while leaders of health delivery organizations may be most interested in evidence about effective strategies to improve particular aspects of care, policymakers may care most about how particular strategies can be used to address multiple improvement targets. Both groups may be interested in the resource implications of various improvement strategies. The research community may be most interested in evidence gaps. Clinicians, patients, and their advocates may find value in identifying areas for improvement that fall within their control and understanding more broadly the evidence for quality gaps and QI. All readers of these reports might expect a deeper understanding of the nature and extent of quality gaps, as well as both targeted and systemic changes necessary to close them.

In addition, this series culminates with two reports developed by the series overview investigators—a summary report intended to show how topics relate and complement each other, which is accompanied by the topic executive summaries,1 and this methods report synthesizing lessons learned that cut across the topics, with the goal of describing the state of the science of QI and the implications for each of the targeted audiences. Thus, this new series is titled: “Closing the Quality Gap: Revisiting the State of the Science.”

### Topic Selection

The leaders of AHRQ portfolios on comparative effectiveness, prevention and care management, value, health information technology, patient safety, and innovation nominated topics for inclusion in the Closing the Quality Gap series. In selecting topics, they considered:

- The ability to focus and clarify the topic area
- Relevance to QI and a systems approach
- Amenability to systematic review
- Low likelihood of duplication and/or overlap with other known or ongoing work
- Relevance and potential impact in improving care
- Fit of the topics as a whole in reflecting the AHRQ portfolios.
- Relevance to system and delivery reform provisions in health care reform legislation under the Patient Protection and Affordable Care Act (ACA)32

Consistent with AHRQ's mission, particular consideration was given to relevance with respect to current trends in health care and the potential for high impact on patient outcomes. Emphasis was also placed on topics that would provide information for rewarding high-quality care through measurement and reporting, key tenets of the ACA legislation. To be selected for the series, topics needed to be “ripe” for systematic review, which is a tool to build a knowledge base and inform decisionmaking.

### Topics

AHRQ selected eight topics for the current series, which reflect its priorities and portfolios:

- Effects of bundled payment systems on health care spending and quality of care (Bundled Payment), by the RAND EPC33
- Patient-centered medical home (PCMH), by the Duke EPC34
- QI interventions to address health disparities (Disparities), by the Vanderbilt EPC35
- Comparative effectiveness of medication adherence interventions (Medication Adherence), by the RTI International-University of North Carolina EPC36
- Public reporting as a QI strategy (Public Reporting), by the Oregon EPC37
- Prevention of healthcare-associated infections (HAI), by the Blue Cross and Blue Shield Association Technology Evaluation Center EPC38
- QI measurement of outcomes for people with disabilities (Disability Outcomes), by the Minnesota EPC39
- Interventions to improve health care and palliative care for advanced and serious illness (Palliative Care), by the Johns Hopkins EPC40

In “Priority Areas for National Action: Transforming Health Care Quality,” the IOM used a systematic process and available evidence to identify 20 priority areas for focusing efforts to improve health care quality in the United States.5 These 20 areas informed the clinical topic areas of the original Closing the Quality Gap series and are relevant to the topics of this new series. Like the IOM priorities, the Closing the Quality Gap series topics include clinical topic areas, populations of interest, setting types, and cross-cutting strategies, and also collectively extend across the full spectrum of health care. In addition, the topic areas touch on the further recommendations of the IOM committee regarding disparities, measures development, and evidence review.

The topics of the Closing the Quality Gap series are also relevant to ongoing initiatives in health care, including the National Quality Strategy (NQS),41 and the system and delivery reforms outlined in the ACA.42 The NQS established three aims for the U.S. health care system: better care, healthy people and communities, and affordable care. It also identified six priorities for QI, which are reflected in the eight series topics:

- Making care safer by reducing harm caused in the delivery of care (HAI)
- Ensuring that each person and family is engaged as a partner in care (Public Reporting, Disparities, Palliative Care, HAI, Medication Adherence)
- Promoting effective communication and coordination of care (Disability Outcomes, Disparities, Palliative Care, PCMH)
- Promoting the most effective prevention and treatment practices for the leading causes of mortality, starting with cardiovascular disease (Disparities, PCMH, Medication Adherence)
- Working with communities to promote wide use of best practices to enable healthy living (Disability Outcomes, PCMH)
- Making high-quality care more affordable for individuals, families, employers, and governments by developing and spreading new health care delivery models (Bundled Payment, Medication Adherence)

The ACA includes many provisions to spur innovation, improve the delivery of health care, and promote the generation and use of evidence in decisionmaking and programs. It also emphasizes health care quality, system efficiency, and costs. Specific provisions related to the Closing the Quality Gap topics include support of the medical home model, bundled payment demonstration projects, data collection on health disparities, development of quality measures, improvement of public reporting of quality and performance, grants to implement medication management services, reducing Federal payment for certain hospital-acquired infections, and continued support of the Aging and Disability Resource Center initiatives. With the ACA emphasis on health care quality and explicit support of evidence-based practices and programs, it is hoped that evidence synthesis of these topics will provide additional information to decisionmakers and other stakeholders as they move forward with these initiatives.

Finally, the focus of some topics, such as Disparities and Disability Outcomes, are specific to priority populations that reflect AHRQ's legislative mandate to improve health care in Medicare, Medicaid, and the Children's Health Insurance Program, as well as ongoing AHRQ activities such as producing the National Healthcare Disparities Report and National Healthcare Quality Report. For other topics, such as HAI and PCMH, the timing of this series allowed teams to build on or complement ongoing work.

## Series Key Questions and Framework

Each topic for the series is broad and requires choices among numerous scope options to balance a wide range of considerations and ultimately yield a report that provides stakeholders with information that is useful, relevant, and actionable for improving quality of care. To help guide this complex scoping task, the topic teams relied on an overarching framework and set of Key Questions common to all topics within the series.

Each topic team considered all scope options in light of specific prioritization criteria that were described by the earlier IOM National Priorities Committee, with the goal of ensuring that the original series reported actionable information that could be used in the near term to achieve improvements.5 For the current series, these criteria were extended based on additional considerations relevant to the current health care delivery system (e.g., focus on value in health care). The final set of criteria used for the current series were:

- Impact: What opportunities exist for a sizable improvement in patients' health and well-being (the quality gap)? What are the economic implications?
- Improvability: What strategies might be expected to reduce quality gaps and improve the value of care delivered?
- Inclusivity: What is the relevance of the topic to patients, conditions, or settings that are underrepresented in research?

With these criteria in mind, the topic teams used a set of series Key Questions (KQs) to guide their decisions about topic scope, Technical Expert Panel composition, analysis, and reporting (Figure 1).

Figure 1 Analytic sequence of Closing the Quality Gap series Key Questions for topic scope development

KQ = Key Question; PICOTS = populations, interventions, comparators, outcomes, timing, and setting

This figure illustrates the flow and relationship of series key questions for scope development of each of the topics in the “Closing the Quality Gap” series. Starting with the boxes on the left is Key Question 1, The Quality Gap, which is addressed by three elements: (1) Information/Data, achieved through measuring, (2) Incentives, or influencing, and (3) Infrastructure & Processes for improving. Key Question 1 flows to Key Question 2, Target Audience(s) at two levels of implementation: Macro, which includes Policy/Market and Organization, and Micro, which includes the Clinician and the Patient. Key Question 2 flows into the final Key Question 3 at the right of the figure, titled Evidence Available. This is addressed by the State of the Science which incorporates Concepts, Content—including PICOTS, Methods, and Context-sensitivity.

KQ1 for the Series: What are the quality gaps targeted by this review, and how might each gap be approached to lead to improvements?

KQ2 for the Series: Who are the likely stakeholders who could act upon each gap, and what evidence will they need? What are the likely levels for implementation of results from the topic report? Consider macro-level audiences (e.g., public policymaking, organizational policymaking) and micro-level audiences (e.g., clinician, patient), and their potential leverage in using the evidence.

KQ3 for the Series: From an initial exploration of the potential literature, what is the state of the science for the topic area and gap? What populations, interventions, comparators, outcomes, timing, and setting (PICOTS) are relevant to the topic? How has the topic been studied in terms of concepts (e.g., logic models, relevant theories), methods (e.g., primary data collection study designs available), and context-sensitivity?

The first of these KQs examines how each quality gap might be addressed through improvement activities. As shown in the first box of Figure 1, there are three core approaches (“3 I's”) to achieving improvements. These stem from a quotation from Victor Fuchs, a renowned health care systems researcher, who said that real reform “requires changes in the organization and delivery of care that provide physicians with the information, infrastructure, and incentives they need to improve quality and control costs” (italics provided by methods report authors).43 In today's complex health system, these leverage points for improvement apply beyond the physician to include other clinicians, systems managers, and patients themselves. As a result, these three general approaches are hypothesized to address quality gaps (KQ1) by:

- Measuring quality: gathering information or data on quality.
- Influencing quality: creating incentives for better quality.
- Improving quality: implementing changes to infrastructure, processes, and other elements of the delivery system. (Often interventions in this category are aimed at changing clinician or organizational behavior at a local level.)

For each topic, these approaches may be matched to the applicable target audience(s) at the expected level(s) of implementation (macro or micro), shown in Figure 1 (KQ2). Further, the review of literature about each topic will build from the state of the science (KQ3) available on specific strategies to implement the general approach.

In addition to these KQs developed to help guide decisions about topic scope, we developed an overarching organizational framework for the series to help specify potentially relevant areas of study for each of the topics (Figure 2). This framework depicts the approach used for all topics to summarize important aspects of the evidence. It also conveys the relationships among the topics, helping to identify cross-cutting lessons across topics for QI science. It further helps ensure use of a common lexicon throughout the series.

Figure 2 Closing the Quality Gap series analytic framework to summarize applicable areas for each topic

This figure illustrates how the elements of scope for each topic relate to one another, and provides a common framework across all topic areas in the series. On the far left the first element asks if the “Topic emphasis [is to] close the quality gap?” This question is addressed by three elements: Information, Incentives, and Infrastructure/Delivery System. These three elements are directed at target audience(s). The target audiences can be at the macro level, which includes policy and delivery organization, or micro, which includes the clinician and the patient.

For each series topic, the topic team also considered potential audiences, levers for action, and the state of the science. The topic teams balanced considerations related to stakeholder input about the most relevant interventions, outcomes, and comparisons; ongoing work; feasibility; generalizability; and impact. For example, when considering potential questions and analyses, the team conducting the Medication Adherence review considered including analysis of factors that could potentially affect implementation, such as time limitations, staffing patterns, and expertise in behavior change; intervention characteristics, such as complexity, that might promote or hinder rapid dissemination; the impact of provider type on outcomes; analysis by type of intervention rather than by condition; cost-effectiveness analysis; and a number of subanalyses related to population characteristics, intervention characteristics, and methods of outcome ascertainment. In the end, the review did not include all of these analyses, but rather focused on a broad approach of analysis of interventions across conditions and included observational studies to provide more guidance for strategies to improve health care quality.

The teams also considered the “sweet spot” for their topic, where an evidence review had a reasonable expectation of netting useful information for specified stakeholders who are empowered to act on that information to close the identified quality gap. Stakeholders were specified as end-users of the reports and people who would be impacted by the report or topic. These included patients/consumers, health care providers, health care delivery organizations, policymakers, and researchers. Each topic team engaged a group of stakeholders to provide input during development of topic KQs and the review protocol.