# Implications for Future Evidence Reviews

The Closing the Quality Gap series topics were reviewed by teams from eight Evidence-based Practice Centers (EPCs), each bringing to bear extensive experience with systematic reviews and comparative effectiveness. Although conducting their topic reviews separately, the EPCs were guided by a common methodology45 and the overarching framework (Figure 2) developed for this series to refine each topic's scope. They were further guided by the series overview investigators in addressing common challenges and adapting methods. The experience of all eight topic teams—combined with the “view from above” afforded the series overview investigators—provides lessons for how to better adapt traditional systematic review methods to complex topics and interventions in future evidence reviews.

All of the topic teams had significant challenges applying aspects of the EPC program Methods Guide to their topics.45 The traditional method guidance works well for clinical treatments but has not been fully developed to support reviews of topics related to organization and systems interventions. In addition, the experience of leading this series points to the potential need for separating this diverse set of topics into subgroups that might each require different guidance on effective and efficient systematic review methods. The series analytic framework (Figure 2) may be a starting point for organizing subgroups with needs for different adaptations to the Methods Guide, but it does not address the “how” to do reviews for each of these groups. That work remains to be done, although we have insight about what methods areas diverge most from the traditional guidance. The subsequent six lessons target the most pressing methods areas for reviews of complex interventions aimed at improving health care quality.

## Sensible Scoping: Key Questions, Frameworks, and Logic Models for Complex Topics

All of the topic teams experienced significant challenges in molding the scope of their topics (“scoping”). The upfront efforts to refine Key Questions required numerous iterations. The series analytic framework itself (Figure 2) was less useful in this effort than was anticipated, although it did help topic teams stay focused on the potential audiences for their reports. As previously noted, the quality levers (i.e., information, incentives, infrastructure) were most useful for categorizing topics for later cross-topic analysis and summary (as in this methods report). In the future, designating a formal topic refinement phase prior to the systematic review phase may be a crucial step for such complex topics in order to shape the topic with input from a panel of experts/stakeholders and the public.46 It also would provide time to explore the feasibility of the proposed topic scope in light of the allotted timeframe, available resources, and stakeholder needs.

While the series analytic framework's quality lever categorization may not have helped the topic teams with their scoping efforts, we observed common challenges and adjustments to the traditional methods for topic scoping for the infrastructure and incentive lever categories. This observation suggests that some common adaptations of the traditional EPC review methods may be possible for future topics that fall within these categories. In particular, the teams for the Disparities, Palliative Care, Patient-Centered Medical Home (PCMH), Healthcare-Associated Infections (HAI), and Medication Adherence topics (infrastructure category) had the benefit of adopting methods for defining health care quality interventions that were developed as part of the original Closing the Quality Gap Series, such as use of the quality improvement (QI) strategies taxonomy for describing interventions targeted at patient, provider, or organizational behavior change (Appendixes A and D).8

Traditionally, the EPCs have used the PICOTS categories, which identify population, intervention, comparator, outcomes, timeframe, and setting to guide scoping of systematic review topics.45 These categories assure appropriately comprehensive formulation of inclusion and exclusion criteria for the review. Developing an analytic framework further supports specification of each element of PICOTS. EPCs create the analytic framework to show how an intervention is hypothesized to influence a population's outcomes. However, the topic teams for this series found that the PICOTS categories did not completely cover their scoping needs. Indeed, many of the teams went beyond an analytic framework specifying PICOTS for their topics and developed a logic model hypothesizing mechanisms through which interventions and context interact to impact outcomes. Both of the incentive quality lever topics developed logic models showing the sequence of influences of information or payment structures, first on care delivery organizations, then on individuals acting within those organizations, and ultimately in potential effects on patient behavior and outcomes. Both of their logic models also included design features and characteristics of the payment bundle or public report as a distinct set of variables to collect. The Bundled Payment logic model was adapted from a previous EPC review on quality-based purchasing.47 Future methods guidance could provide a catalog of logic models used in systematic reviews for these types of incentive interventions and determine common elements to include for future reviews.

Teams for several of the infrastructure topics also developed logic models to help guide their reviews. The Disparities team developed a simple model hypothesizing how QI interventions may change processes or outcomes for selected conditions or populations, thereby reducing disparities with respect to those outcomes. The PCMH team developed a model hypothesizing mechanisms by which comprehensive PCMH interventions impact outcomes. The HAI team adapted a logic model from Shekelle and coauthors to hypothesize how organization and health system factors, patients, settings, clinicians, system leaders, and characteristics of QI strategies interact to impact first care processes and then outcomes, including economic outcomes.48 The Medication Adherence team developed a model of interactions among patients, interventions, modifying effects of intervention characteristics, medication adherence, and ultimately outcomes. This model also included adverse events in the causal chain, as did the Public Reporting, Disparities, and PCMH models.

Logic models describe the ways in which an intervention is hypothesized to achieve specific changes through a causal chain of actions and effects.49 These models enrich the typical EPC analytic frameworks by incorporating factors beyond the clinical logic (e.g., adding intervention component logic, potential interactions with context surrounding the intervention, and broader sets of outcomes of QI efforts that are likely to be of interest to multiple stakeholders). Incorporating a logic model into the scoping exercise acknowledges its fundamental importance in identifying and assessing the potentially complex evidence base for these types of topics. It also facilitates generalization of evidence from one intervention, setting, or context to another by helping elucidate the mechanisms through which QI activities achieve change (or fail to do so). This, in turn, can help QI practitioners select interventions that are likely to be effective in their own particular circumstances.49,50 For example, the logic model developed for the Public Reporting review postulated that improvements in health care quality might be achieved both through changes in patients' behavior (e.g., through choice of providers) and through changes in health care delivery structures and processes (e.g., engaging in QI activities, changing policies or guidelines). Evidence from the review supported the hypothesis that providers and systems administrators make changes in response to public reporting, but the review found little evidence that patients changed their behavior in response to publicly reported information. Evidence from qualitative studies provided further insight, suggesting that the lack of behavior change by patients may be explained by frequent mismatches between report content, format, and timing and patients' informational needs at the time they make various health care decisions. By identifying two distinct mechanisms through which public reporting is hypothesized to lead to quality improvements, the logic model, combined with this evidence, points to two avenues for achieving quality gains through public reporting: by targeting reporting initiatives to providers and administrators, and by carefully matching report content, format, and timing to patients' informational needs. The evidence also suggests ways in which the logic model may be refined (e.g., specifying patient decision points), furthering a cycle of theory, testing, and refinement.

Thus, in the case of these complex topics directed at health care quality enhancement, we recommend extending the PICOTS categories to add an “L” for “logic” model and prioritizing this category right after consideration of the population whose health is of interest. We further recommend adding a “C” for context,48,51 given the potentially important impact of contextual factors on the effectiveness of systems-level interventions. The acronym for health care quality reviews would then become “PLICCOTS,” although a simpler naming convention would be desirable as a mnemonic. The overarching question is: For a defined population, what is the logic argument that a complex intervention works better than its comparator in a given context to produce outcomes (of interest to QI) within a time period and setting?

## Challenges in Defining Complex Health Care Interventions and Concepts

Differences in the definitions and terminology used for key concepts within the universe of health care QI research pose an additional challenge to systematic reviewers. For this series, topic teams typically developed statements to define their concepts and then searched the literature to find evidence relevant to the underlying meaning of those statements, even when the specific terminology used varied. For example, the PCMH review authors searched for and included studies that were judged to meet the intervention definition but did not necessarily use the term “medical home.” The merit of this approach is reflected in the fact that this “search by meaning” strategy more than doubled the relevant literature identified, compared with a “search by term” strategy. Future systematic reviewers may expand the yield of literature searches through similar “search by meaning” methods.

A related challenge lies in the different ways in which a single term can be used by different groups. Concepts and definitions of QI itself vary. The Closing the Quality Gap series took a broad view of QI interventions as those that could be described as aimed at improving quality, with quality defined according to the Institute of Medicine's very inclusive definition of care that is effective, efficient, patient centered, timely, safe, and equitable.6 However, some of the peer reviewers of the series reports conceptualized QI more narrowly, focusing on distinctions between activities that do and do not typically require research regulatory oversight (i.e., review by an Institutional Review Board). The U.S. Department of Health and Human Services has provided guidance and considers “quality improvement” as work using tested interventions to improve care or using data for clinical or administrative purposes, as opposed to “research” designed to develop or contribute to generalizable knowledge.52,53 Far from being abstract, this type of semantic ambiguity impacted the series reports. For example, in response to peer review discomfort with the QI terminology, the authors of the Palliative Care review revised the way they referred to their topic as “health care and palliative care” interventions to improve quality and patient outcomes.

Similarly, the HAI team specified terminology to distinguish preventive interventions from QI strategies in response to expert and stakeholder confusion about the continuum of conceptual leverage points for improving quality and assessing evidence. The team took the preventive intervention (the infection control practice demonstrated to reduce the incidence of HAI) as a given and pointed to other sources for that evidence. Their review assessed QI strategies targeted toward effective adoption of these preventive interventions. Their QI strategy definition drew from the earlier Closing the Quality Gap series.

Given ambiguity in the use of terminology within the QI field, future systematic reviews will be strengthened by addressing that ambiguity in research publications by clearly defining core concepts, explicitly calling out any definitional ambiguity within the body of literature reviewed, and placing reviews in the context of alternative conceptualizations.

## Assessing Individual Study Quality

The paucity of existing tools to evaluate such a diverse set of heterogeneous studies created a challenge for the series topic teams in trying to assess the quality of individual studies included within their reviews. In addition, when tools were available, uneven reporting of important aspects of the primary studies limited the investigators' ability to accurately assess study quality.

For example, the HAI team spent significant time developing strategies to assess statistical analyses conducted in the primary studies included within their review. The Public Reporting team also noted that the usual EPC Methods Guide procedures for assessing study quality did not apply to the designs of all the primary studies included within their review, necessitating development of additional criteria.45 They then needed to evaluate how consistently the adapted criteria were applied by data abstracters before proceeding with the full review. The Palliative Care team found that many studies had small sample sizes, reported only on specific aspects of outcomes, or reported differential findings across multiple outcomes. Even if tools were available for thorough quality assessment of complex health services interventions (and thus far, they are not), most series topic teams found that studies often lacked detail about methods that would be needed for a complete assessment of quality.

Systematic reviews identify important gaps in the available literature. Future systematic reviews can improve research by continuing to report on weaknesses in the underlying evidence base contributing to evidence gaps, and ways to address these weaknesses to strengthen the evidence base. Improving tools for assessment of study quality can provide an accurate, systematic, and transparent way of assessing the quality of the evidence base. Until these quality assessment approaches are available for QI topics, systematic reviewers should continue to thoughtfully adapt existing tools, and report such adaptations and the rationale in a transparent manner in reports.

## Assessing Strength of the Evidence

The series topic teams also found that although the EPC Methods Guide offered a starting point for assessing strength of evidence across studies, it required adaptation for the complex body of literature on QI of health services.45 In particular, the Bundled Payment team found little guidance available for gauging the strength of evidence related to payment interventions. Another challenge that cuts across series topics was highlighted by the HAI team, which found evidence of publication bias wherein only positive results appeared to be published. The literature in this field also appears to be susceptible to reporting bias, making it difficult to determine whether published studies are presenting all of the interventions and outcomes that were explored. The topic teams at each EPC used general principles to make strength-of-evidence assessments, but further research and development are needed to create tools that guide assessment of both quality of individual studies, as noted above, and overall strength of a body of evidence when synthesizing literature pertaining to complex QI interventions. Ultimately, an adaptation is needed of the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group system,54 similar to that proposed in a methods report on patient safety practices,48 that would answer the question: Does this evidence help me decide whether I can implement this QI intervention in my organization (or other sphere of influence) and get a similar result?

## Meaningful Synthesis and Audiences

Whether a patient or a policymaker, a physician or a hospital manager, each individual with a stake in health care quality needs systematic reviews to present accurate and actionable evidence. Providing meaningful synthesis for key audiences has been a priority for both the individual reports in the series and for this report. While these are simple marching orders to the systematic reviewer, meeting this goal with the available scientific base is tough to do. The topic teams for this series used some innovative approaches to meet this challenge, which could be considered for future systematic reviews on QI topics.

For example, when quantitative studies were largely lacking, the Public Reporting team used qualitative research to address the question of how report characteristics influence the effectiveness of public reporting initiatives. Although not assessed for strength or quality, this qualitative evidence provided readers with a starting place to understand what report characteristics might be important to consider in designing or evaluating a public reporting initiative. Future reviews that include and synthesize qualitative research may improve the applicability of findings and shed light on the impact of various contextual factors.

The rapid growth in evaluations of the PCMH model presented a challenge to the team reviewing that topic, one they met by incorporating a “horizon scan” of upcoming research into the scope of their review. Audiences could then see where evidence is forthcoming to fill gaps identified in the review and could use this information to inform future research and evaluations.

In another example, the HAI and Medication Adherence teams evaluated the effectiveness of interventions both with respect to care processes (e.g., adherence to HAI-prevention best practices, improved medication adherence) and to patient and system outcomes (e.g., infection rates, symptoms, biomarkers, health care utilization), addressing the presumed causal chain between key care processes and ultimate outcomes. Further elucidating the causal chain, identifying enabling factors, and assessing the evidence for these relationships in systematic reviews will better inform the choice of interventions and their application.

To help organize diverse and heterogeneous bodies of literature, the topic teams grouped studies into clusters likely to be meaningful to their audiences, such as evaluating public reporting initiatives by setting (e.g., hospital, long-term care), evaluating medication adherence interventions by medical condition, and structuring findings by targeted outcome (e.g., distress for palliative care). Future reviews could consider other ways of grouping studies, such as the theoretical underpinnings of interventions based on models and/or frameworks relevant to key stakeholders. These approaches to synthesis and reporting help those who may implement the evidence understand its applicability to their context.

## Methods for Synthesis

In addition to the challenges in defining complex interventions, the topic teams faced challenges in methods of synthesis. They encountered complexity in the systematic reviews with respect to the multifaceted nature of interventions, diversity of study designs, variation in the inclusion of contextual factors, and differing models of implementation. All these factors contribute to heterogeneity in results, limiting the ability of topic teams to quantitatively synthesize evidence. The teams took different approaches to managing this complexity and synthesizing the evidence in logical ways.

Based on this experience, the topic teams identified areas for methods development to improve future reviews and their ability to answer questions relevant to decisionmakers. They indicated the need for methods adapted to the QI field; such areas could include accounting for extreme heterogeneity in intervention designs, features, context, and implementation strategies, and inclusion of qualitative research or mixed-methods studies.