# Technical Expert Panel

Each Evidence-based Practice Center team acted as a technical expert for the cross-topic synthesis and integration of evidence that comprises this Methods Research Report.

Bundled Payment: Effects on Health Care Spending and Quality

The RAND Evidence-based Practice Center

The Patient-Centered Medical Home

The Duke Evidence-based Practice Center

Quality Improvement Interventions To Address Health Disparities

The Vanderbilt University Evidence-based Practice Center

Medication Adherence Interventions: Comparative Effectiveness

The RTI International-University of North Carolina Evidence-based Practice Center

Public Reporting as a Quality Improvement Strategy

The Oregon Evidence-based Practice Center

Prevention of Healthcare-Associated Infections

The Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center

Quality Improvement Measurement of Outcomes for People With Disabilities

The Minnesota Evidence-based Practice Center

Improving Health Care and Palliative Care for Advanced and Serious Illness

The Johns Hopkins Evidence-based Practice Center