# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project. We thank John Ovretveit for motivational discussions about improving evidence synthesis of complex interventions in ways that support managerial decisionmaking. We also thank Beth Collins-Sharp and Margaret Coopey for their assistance in launching this series. We are grateful to Victor Fuchs for candid critiques of quality improvement research, Julia Lonhart for coordination with the eight contributing topic teams, and Holly McDonald for helping review and summarize reports. We also thank the author teams from each of the reports in the Closing the Quality Gap series for undertaking their challenging topics, while maintaining willingness to support the lead EPC effort by the series overview investigators to identify cross-cutting lessons.