# Cross-Topic Summary

To summarize findings across topics, we filtered the evidence from the topics in three steps and identified overarching cross-topic lessons. First, we assembled a brief structured abstraction of each series report (Appendix A, Topic Findings by Report) to answer the following questions:

- How was the central topic defined for this review?
- What is the quality gap addressed by this topic?
- Who is interested in the topic?
- What evidence are stakeholders seeking?
- What is the scope of the review?
- What were the key findings by Key Question?

Second, for each of the topics, we organized the evidence according to audiences reflected in the series framework: patients/consumers and their caregivers, clinicians and health care professionals, quality leaders from health delivery organizations, and policymakers (Appendix B, Focus on Action: Key Messages for Improving Quality). Third, we further categorized findings from each topic in terms of research gaps, messages for researchers, and messages for research funders, another key policymaker audience (Appendix C, Advancing the Science: Key Messages for Informing Further Research).

These exercises in digesting information from the series reports provide the first cross-topic lesson: every topic has relevance to many different potential players in health care, with potential followup actions possible for those looking to improve quality as well as those wishing to advance the state of the science. All audiences can actively engage in efforts to improve health care quality. While this finding may seem obvious given the high profile of the topics chosen, the likelihood of action is heightened through recognition of how the pieces of evidence link to specific audiences. The series framework demands this type of lens.

Similarly, the series framework posited that the topics could be linked to three quality levers (information, incentives, and infrastructure). In synthesizing lessons learned across topics, we asked: How do the topics relate to each lever? Why is it useful to categorize topics according to the lever for potential action? Often quality improvement (QI) work targets specific interventions, populations, or outcomes, without considering a broader context of actions and responses of people and organizations. By looking at a health care topic from a higher level of analysis, the second cross-cutting lesson emerges: that quality at the scale of a health care system requires action from each lever. We explore this idea in more depth by organizing the topics into the main quality levers to which each relates, while also pointing out some of the spillover between categories.

## Topic Coverage by Quality Lever

The framework for the Closing the Quality Gap series rests on three levers for affecting quality of health care: information, incentives, and infrastructure.43 The topics in the series each relate to a primary lever (Table 1), with the other two levers often playing a supporting role. For example, the patient-centered medical home (PCMH) is classified as an infrastructure lever because it is a model of primary care delivery, one hypothesized to improve quality through its key components supported through appropriate infrastructure of systems, teams, principles, and processes. However, PCMH does not develop in a vacuum. Commercial payers are creating incentives for this form of care delivery (incentive quality lever). To provide some assurance to payers—and patients—that an organization is delivering care in accordance with the principles of PCMH, accrediting organizations seek ways to evaluate the “insides” of PCMHs through quality measures (information lever).

Table 1 Closing the Quality Gap series topics and quality levers

Information: Measuring Quality | Incentives: Influencing Quality | Infrastructure: Improving Quality
Disability Outcomes | Bundled Payment Public Reporting | Disparities PCMH Medication Adherence HAI Palliative Care

HAI = healthcare-associated infection; PCMH = patient-centered medical home

### Information

The report on Disability Outcomes focuses exclusively on information development, although all of the reports in the series supply information that may be used to improve quality. This review sought to identify measures available and to measure gaps for a specific group of people—those with disabilities—for the purpose of improving the quality of their health care and their experiences with the health care system. Measures shed light on areas where more improvement work is needed. Without measures that reflect the interests of this population, it is less likely that their needs will be met through the care they receive. Furthermore, without appropriate measures, it will be impossible to monitor how the health care system is performing with respect to outcomes that are meaningful and important to people who have disabilities. Evaluating care through outcomes well matched to the population of interest is critical to QI efforts, as ultimately those efforts strive to make improvements in ways that directly and meaningfully benefit patients.

### Incentives

The Bundled Payment and Public Reporting topics focus on incentives to provide high-quality care (care that is safe, effective, patient centered, timely, efficient, and equitable6) and make improvements leading to better care, healthy people and communities, and affordable care.41

The report on Bundled Payment seeks to examine the influence on organizations of changing the approach to paying for care, and how organizational response to such new incentives either enhances or deters health care quality, including efficiency.

The Public Reporting topic may, at first, seem to fall within the rubric of the information lever. Indeed, the substance of public reporting—quality measures—is information that demonstrates performance of the health care system. However, the focus of this topic is how public reporting of such information affects behaviors of people and organizations in ways that potentially improve the quality of care received by patients. The topic review seeks to answer the questions: How are care seeking and purchasing behaviors affected by reports of health care quality? How is the behavior of a health care delivery organization influenced by the presence of public reports of its quality? Do the behavior changes of individuals seeking, purchasing, or managing care translate to observable improvements in care and outcomes? At the core of these inquiries is the question of whether public reporting incentivizes improvements in the health care system in a way that benefits patients. Information is the centerpiece for the incentive, but the ultimate aim of the evidence report on Public Reporting is to understand how these approaches affect quality-enhancing behaviors, as well as examining instances of no effect or unintended adverse effects.

### Infrastructure and Delivery System

The remaining five reports in the series examine interventions that modify the infrastructures undergirding health care provision, often targeting behaviors. The Disparities, Healthcare-Associated Infections (HAI), and Medication Adherence reports address how organizations can improve these aspects of care and the intervention characteristics associated with successful improvements. The Palliative Care report focuses on interventions to improve the care of one particular population—patients with serious or advanced illness who have few prospects for cure. The final topic focuses on PCMH, an intervention that aims to improve the quality of care through changes in health delivery infrastructure.

## Patterns Across Reports

Regardless of quality lever categorization, a third cross-cutting lesson is that interventions and contexts were always complex. To reduce the complexity and develop guidance for future systematic reviews (third chapter) and next steps for the QI field (fourth chapter), it is instructive to look at patterns with respect to five relatively common aspects of the evidence base reviewed for the series: intervention strategies, characteristics of those interventions, the impact of contextual factors on effectiveness of QI efforts, potential harms from QI activities, and QI impacts on health disparities and vulnerable populations.

### Intervention Strategies

Seven of the eight series reports examine the effectiveness of QI interventions: three reports focus on a particular type of intervention (Bundled Payment, Public Reporting, and PCMH), while four assess evidence about a wide range of interventions applied to a particular setting or topic area (Disparities, Palliative Care, HAI, and Medication Adherence). Table 2 summarizes the range of interventions examined in these seven reports, using the QI intervention strategy taxonomy developed for the original Closing the Quality Gap series (Appendix D).8 The Disability Outcomes report focuses on identifying outcomes measures and is not included in the table. This report shares a feature with several of the others by including attention to care coordination as an organizational strategy aimed at addressing quality problems across settings and providers.

Table 2 Types of quality improvement strategies studied and evidence of benefit for Closing the Quality Gap series topics

Intervention Type^a^ | Bundled Payment | PCMH | Disparities | Medication Adherence | Public Reporting | HAI | Palliative Care
Patient education | | | ■^b^ | ■ | | □ | ■
Promotion of self-management | | | □ | ■ | | □ | ■
Patient reminder systems | | | | ■ | | □
Audit and feedback | | | | | ■^c^ | ■ | □
Provider education | | | □ | | | ■ | □
Provider reminder systems | | | | | | ■ | □
Facilitated relay of clinical data to providers | | | | □^d^ | | □ | □
Organizational change | | ■^e^ | □^f^ | ■^g^ | | ■ | ■
Financial incentives, regulation and policy | ■^h^ | | | ■^i^ | | □

HAI = healthcare-associated infections; PCMH = patient-centered medical home

a Intervention types based on taxonomy from the original Closing the Quality Gap series (Appendix D).8

b Language-concordant education.

c Public reporting.

d Pharmacist or physician access to patient adherence data.

e PCMH.

f Case management, collaborative care.

g Case management.

h Bundled payment.

i Payment policies, copayment reduction.

Note:

□ Indicates that a particular strategy has been examined for the topic. If applicable, footnotes contain further details of the strategy.

■ Indicates that evidence was found in the topic report for benefit of the strategy.

The Disability Outcomes report did not evaluate the effectiveness of quality improvement interventions and therefore is not included in this table.

The four reviews that focused on interventions in particular settings or topic areas (Disparities, Palliative Care, HAI, and Medication Adherence) included multifaceted interventions, typically with two to five intervention components. The most common types of QI strategies studied were patient education, promotion of self-management, organizational change, provider education, and provider reminders. In most studies the comparator was usual care or no intervention. Due to the number and diversity of interventions, it was difficult to identify the effect of one component in relation to others. As the authors of the HAI report noted, this situation reflects common practice.

Interventions could be targeted at patients, providers, health systems, and/or health policies. In many studies interventions had multiple targets, although most did not target the full spectrum of actors that could potentially impact health care quality. Except in the HAI review, many interventions targeted patients (with or without additional targets). Single-target interventions were typically directed at patients via education, self-management, and reminders. Similar types of interventions, such as education and reminders, were reported in the HAI review, although they were targeted at providers rather than patients.

These four reviews generally found promising results for interventions that included an educational component. Evidence from the Disparities and Medication Adherence reports indicates that tailoring or enhancement may confer benefit, in particular language concordance and visual aids. For the three reports that include interventions targeted to patients or caregivers (Disparities, Palliative Care, and Medication Adherence), self-management and patient education interventions conferred benefits. Organizational change (such as collaborative care, case management, and care coordination) also demonstrated benefit for improving some clinical outcomes or care quality. Interventions that focused solely on the provider as a target tended to demonstrate less benefit, except for HAI.

Inconsistent results were seen for some strategies across the series. In the HAI review, the addition of audit and feedback to baseline strategies (organizational change and provider education) had consistent benefit for lowering infection rates. However, similar results were not found for use of this intervention in the Palliative Care and Disparities reviews, although audit and feedback were less frequently studied in those areas and not necessarily used in conjunction with the same baseline strategies. Public reporting, a type of audit and feedback at a more global and visible level, was associated with a reduction in mortality rates and improvement in quality and process indicators, but the evidence was generally insufficient to draw conclusions about the type of report characteristics that impacted outcomes. While no firm conclusions could be made, the Public Reporting report notes that information that is relevant, readable, and clear is useful for decisionmakers, and that the mode of delivery may affect the use of public reports. However, the studies included in their review either did not or were not able to further analyze characteristics of public reporting; issues such as timing, inclusion of relevant or specific information, and mode of delivery could impact the usefulness and effectiveness of this strategy. Other issues that could contribute to apparent inconsistencies both within an evidence report and across the series pertain to the diversity of study designs included, differences in interventions within a QI taxonomy category and ways they were combined, and the potential impact of contextual factors.

Two reviews in the series, Medication Adherence and HAI, examined the outcome of adherence. Both included interventions focused on a particular target—the patient in the case of Medication Adherence and the health care provider in the case of HAI. Across clinical conditions, both reviews found that education, reminders, and organizational changes were associated with improved adherence.

### Intervention Characteristics

Intervention characteristics were examined in five reviews (Table 3), but for four reviews there was insufficient evidence available to draw conclusions about characteristics associated with effectiveness, and one review (Palliative Care) identified interventions according to targets (pain, communication, transitions) or model of care (integrative or consultative). (Assessments on these dimensions are highlighted in Appendix B.) The Bundled Payment review found no studies that analyzed system effectiveness by intervention design features. Analysis by the topic team found that quality metrics and pay-for-performance incentives were rarely incorporated into bundled payment programs, so the team could not examine the relationship of these features to outcomes. Like Bundled Payment, the Public Reporting review found little quantitative evidence about whether and how intervention features—in this case, characteristics of reports—affected outcomes. However, evidence from qualitative studies suggested that relevance to patients, readability, and clarity of presentation were important to patients' use of publicly reported quality information. The PCMH review examined the aspects of the PCMH model that were implemented in each intervention but did not attempt to determine which combinations of these components were most effective. Although a majority of studies (21 of 27) included all seven major PCMH components within the intervention, the strategies employed to implement those components varied widely (51 different strategies across 27 studies). Like the other three topics, the Medication Adherence review found little evidence that addressed differential effectiveness of intervention features. Across four randomized controlled trials that addressed this research question, there was insufficient evidence about the effects of intervention agent, mode, or intensity on medication adherence. The Medication Adherence review further assessed frequency of specific patient-level intervention components from an existing taxonomy (e.g., knowledge-based activities, awareness-based pursuits, self-efficacy enhancement, and contingent rewards) and novel additional components present in some of the interventions (e.g., shared decisionmaking, gain sharing).

Table 3 Additional assessment areas explicitly targeted in Closing the Quality Gap topic reports

Topic | Intervention Features | Context | Potential Harms | Disparities/Vulnerable Populations
Bundled Payment | ■ | ■ | ■
PCMH | ■ | | ■
Disparities | | | ■ | ■
Medication Adherence | ■ | | ■ | ■
Public Reporting | ■ | ■ | ■ | ■
HAI | | ■ | ■
Disability Outcomes | N/A | N/A | N/A | ■
Palliative Care | ■^a^

HAI = healthcare-associated infections; N/A = not applicable; PCMH = patient-centered medical home

a Features studied were intervention target (e.g., pain, communication, transitions) and palliative care model (integrative vs. consultative).

Note:

■ = Assessment area for this topic report.

### Contextual Factors

Three reviews examined the impact of contextual factors on QI interventions (Table 3). The Public Reporting review found that public reporting more readily led to quality improvements in competitive markets and among low-performing organizations and providers (high strength of evidence). The Bundled Payment review found that few studies reported on contextual factors, but some evidence of low strength suggested that the effect of bundled payments in reducing health care utilization was magnified for for-profit providers and for hospitals under greater financial pressure. The most commonly examined contextual factor was patient disease severity, but results were inconsistent about its impact on the effectiveness of bundled payment programs. The authors of the HAI report analyzed the types of contextual factors reported among the 72 studies included in their review but did not attempt to synthesize evidence about how those factors impacted HAI rates or provider adherence to best practices. Overall, the types of contextual factors examined across these topics varied considerably, ranging from economic considerations (for-profit status, financial pressure, market competitiveness) to patient characteristics (disease severity, age, insurance coverage, health needs) and organizational characteristics (leadership, change, resource availability).

### Potential Harms

Six reviews sought information about potential harms associated with QI interventions (Table 3). In general, little evidence was available about potential harms related to QI interventions for these topics. The Bundled Payment and Medication Adherence reviews found few studies that assessed potential harms, limiting the ability to draw conclusions. There was consistent evidence that single-setting bundled payment programs resulted in care shifting to other settings. However, the review authors noted that most current bundled payment programs are now multi-setting, which is expected to reduce incentives for care shifting. The Disparities and HAI reviews found no studies that addressed potential harms, while the PCMH review found only two uncontrolled studies that did so. Two studies of Medicare programs that met PCMH inclusion criteria found that when program costs were considered, the overall cost of care was greater for the PCMH intervention. Although the potential for unintended negative consequences of public reporting was widely discussed, the review authors found only limited evidence examining whether those harms actually occurred. Evidence was mixed, but overall the authors concluded that evidence of no harm outweighed evidence of harm. The most widely examined potential harms were related to provider behaviors that could limit patient access to care (e.g., cherry-picking low-risk patients or avoiding high-risk patients), but the evidence was of low quality and yielded mixed results. Results from all six reviews suggest that further research is needed into potential harms resulting from QI activities.

### Health Disparities and Vulnerable Populations

In seeking to improve health care quality, interventions have the potential to also eliminate disparities in care (specifically targeting the equity goal of the Institute of Medicine definition of quality).6 For example, efforts to improve medication adherence may improve outcomes in some populations, such as minorities and patients with low health literacy. Public reporting may hold promise for reducing disparities by improving the availability of relevant information about facilities and providers that are available to vulnerable populations. While one review focused exclusively on the potential for reducing health care disparities through QI interventions, several other series topic reviews also touched on health disparities by examining the impact of interventions in specific patient groups or vulnerable populations (Table 3). Although the available literature was limited, the Disparities review found some promise for improving health outcomes using collaborative care and targeted patient education interventions, particularly among racial minorities. Similarly, medication adherence improved among black patients with diabetes and depression with use of an integrated care intervention, although these results were from a single study. No evidence is available in the Medication Adherence report about the impact of interventions on the uninsured, other minorities, and low-literacy populations. Results were not consistent on the impact of public reporting on vulnerable populations or health care disparities. Although most studies concluded that public reporting did not contribute to reduced access to care for patients or adverse selection of patients by providers (e.g., cherry-picking, cream-skimming), one study found that public reporting appeared to increase the disparity between white and black or Hispanic patients in the receipt of coronary artery bypass graft surgery. In the future, other initiatives such as PCMH could provide additional evidence about benefit in addressing disparities, and the development of relevant outcomes measures for assessing quality of care in disabled populations could facilitate identification and monitoring of disparities.44 Evidence exists about disparities in the delivery of palliative care; further research is needed into how such disparities may be reduced.