# Conclusion

The Closing the Quality Gap series evaluates the state of quality improvement (QI) science for eight high-priority health care topics, while also providing a window into the evolution of QI research overall. Individually, each of the eight reports synthesizes the most up-to-date evidence about its topic—Bundled Payment, the Patient-Centered Medical Home (PCMH), Disparities, Medication Adherence, Public Reporting, Healthcare-Associated Infections (HAI), Disability Outcomes, and Palliative Care—providing a key resource for stakeholders with an interest in QI in these areas. Taken together, the reports in the series provide a broad view of QI science, revealing trends, advances, gaps, and challenges that are common across topics. While highlighting key results of each topic review, this methods report focuses primarily on this broad view, summarizing take-home messages for key stakeholders, identifying common challenges and solutions across topics, and discussing implications for future evidence synthesis and QI research in light of lessons learned from all eight topic teams.

Looking across the eight series topic reports, we see that many different outcomes have been used to assess effectiveness in QI research, posing a major challenge to reviewers trying to synthesize evidence across studies. In many cases, whether or not an intervention was found to be effective depended on the outcome examined; many interventions demonstrated improvements for one outcome but not others, both within and across studies. Although several topic teams sought to examine the impact of particular intervention features and contextual characteristics on effectiveness, incomplete and inconsistent reporting of these characteristics generally precluded addressing this question. Potential harms from QI interventions were also rarely investigated, as were economic outcomes such as costs, savings, or return-on-investment.

Together, the experience of the eight topic teams points to the difficulty in applying traditional systematic review methods to literature on complex QI interventions, where many different permutations of intervention features and improvement techniques have been tried across a wide range of populations, settings, organizations, and contexts. Heterogeneity in how interventions were described and the choice of outcomes measures further hampered synthesis across studies. Each of the topic teams also identified weaknesses in the quality of the available literature, recognizing that randomized controlled trials are not always feasible or appropriate for evaluating multifaceted QI interventions.

Lessons learned from the series suggest several recommendations to advance the field of QI research. Specifically, these are to develop a core set of outcomes measures for QI research, develop a framework for QI interventions that includes a lexicon for describing interventions and contextual factors, develop measures of context that can be applied broadly, and adapt or develop new methods of studying effectiveness and performing comparative synthesis that are better suited to the complex, context-dependent, systems-level interventions typical of QI research.

Together, the series topics reveal a comprehensive cross-cutting view of QI and a refreshing chance to continue deriving more lessons beyond those distilled in this report and other syntheses.62-64 By conducting these reviews in parallel, we were able to coordinate approaches across topics using an overall improvement framework aimed at gaps in quality and the potential quality levers for shrinking these gaps (i.e., through information, incentives, and infrastructure/delivery system change). By examining commonalities across the individual series topic reviews, this report provides insight into how to advance the state of the science in QI and systematic review of complex interventions, while also making information accessible now that is actionable by key stakeholders working to improve the quality of care in the United States.