# Advancing the Science: Key Messages for Informing Further Research

In this appendix, we summarize take-home lessons from each review that can help guide the direction, methods, or content of future research. These lessons were identified by the Evidence-based Practice Center topic teams who performed the reviews, as well as the Closing the Quality Gap series overview investigators. We summarize lessons separately for research gaps (Table C-1) and messages to researchers (Table C-2) and research funders (Table C-3). For all topics, information is lacking or limited for downstream effects, such as caregiver-related outcomes and financial consequences. In addition, the topic teams analyzed the applicability of their findings to settings, populations, and contexts of interest but not covered by primary studies in their reviews. Gaps and research needs often correspond to these analyses.

Table C-1 Research gaps

Topic | Take-Home Messages To Inform Future Research
Bundled Payment | Little is known about effects of multiple-setting bundled payment programs. A majority of bundled payment programs in the studies included in this review pertained to single settings (e.g., inpatient hospitals, skilled nursing facilities, inpatient rehabilitation facilities) rather than multiple settings or provider types. Recently, interest in bundled payment has focused on this latter type, but thus far little evidence is available about the effects, unintended consequences, design, or context of multiple-setting bundled payment programs. As these programs are implemented, further research is needed to evaluate their effects on spending, quality of care, and other outcomes. Little evidence is available except in single-payer contexts. Most research to date has focused on programs specific to single payers, such as Medicare or non-U.S. public insurance programs. Further research is also needed on bundled payment programs implemented in the context of the multiple-payer environment typical of the U.S. health care system. Effects on patient subgroups are unclear. Evidence from a small number of studies suggests that the effects of bundled payment programs may vary for different patient subgroups. But few studies stratified analyses by patient population or type of service, leaving many questions unanswered. Almost no studies evaluated the impact of specific program design features or contextual factors on the effects of bundled payment programs. This review found almost no evidence to address Key Questions 2 (effects of design features) and 3 (effects of context). This area is ripe for exploration as additional bundled payment programs are implemented and evaluated.
Patient-Centered Medical Home | Research is needed on broader patient populations and outcomes. Most studies evaluated effects in older adults with multiple chronic illnesses; few studies were conducted in pediatric or general adult primary care populations. Effects on quality indicators for chronic illness care and on clinical outcomes are uncertain. These are among the most important outcomes to patients, clinicians, and policymakers. Other gaps in evidence include the absence of data on staff retention, unintended consequences, and direct financial consequences to the practice implementing PCMH.
Disparities | The ability of QI strategies to reduce disparities is unknown. Very little research to date has examined whether QI strategies can be used to reduce health care disparities. What little is available is insufficient to draw conclusions about effective strategies due to weaknesses in study design. Few disparities have been explored other than by racial and ethnic groups. What little evidence is available about the effectiveness of QI strategies in reducing disparities has primarily focused on differences in racial and ethnic groups. Almost no information is available about reducing disparities that are based on other social or demographic characteristics, such as socioeconomic status, age, sex, or disability status. No evidence is available about potential harms from efforts to reduce disparities. This review found no information to address Key Question 2, which focused on reports of unintended negative consequences resulting from efforts to reduce disparities through QI strategies.
Medication Adherence | Several key questions were rarely explored. Few studies examined the medication adherence intervention characteristics that are associated with effectiveness, and only 3 studies examined unintended consequences of medication adherence interventions. Most studies of vulnerable populations focused on patients with particular high-risk conditions or coexisting conditions—in particular, depression with or without other chronic disease. No studies examined the differential impact of medication adherence interventions on racial and ethnic minority groups, low-income and underinsured or uninsured patients, or populations with low literacy.
Public Reporting | The research literature does not reflect the diversity of public reports. Currently, the research literature is dominated by public reporting for cardiac procedures in three States (New York, Pennsylvania, and California) and for nursing homes using the Nursing Home Compare report. Research on these public reporting programs accounted for just under half of all quantitative studies included in this review. Research is needed on other public reports, settings, and geographic locations, particularly as public reporting becomes more common. The literature lacks needed detail about reports and reporting context. Few if any details on the format or context of public reports were published in the literature, limiting analyses of how these factors impacted the effectiveness of public reporting as a QI strategy (Key Questions 5 and 6). Little information was available about how the effectiveness of public reporting varied in different settings and for different types of health care decisions. Greater rigor is needed in study design. Most quantitative studies identified used a before-after design to compare public reporting with a period of time before it was implemented. Although population-based interventions such as public reporting can pose a challenge when selecting a comparison group, the field would be much advanced by development of statistical methods or study designs that enable investigation of when stakeholders (e.g., patients, referring clinicians, purchasers, policymakers) make use of public reports and for which types of decisions. Mechanisms through which public reporting leads to improvements in quality are understudied. Most research on public reporting has focused on its potential harms and observed impact on quality. Few investigations have explored how public reporting motivates or facilitates improvements.
Healthcare-Associated Infections | Evidence is lacking for settings outside the hospital. Although this review aimed to identify evidence pertaining to additional settings, such as ambulatory surgery centers, dialysis centers, and long-term care facilities, no such evidence was identified. Continued gains in methodological rigor are needed. Although the quality of research designs has improved markedly since the 2007 review on this subject,1 a majority of the current evidence is still insufficient to support causal inferences. Greater use is needed of controlled trials and interrupted time series studies reporting data from multiple time points before and after the intervention. Reporting and analysis of contextual information are scarce. Identifying what QI strategies work in which settings will require an understanding of how context impacts implementation. Yet information about many key contextual factors was often lacking in studies, and much of what was reported was anecdotal. Quantitative analyses including contextual factors were relatively rare. Economic impact was rarely studied; methods were inconsistent across studies. Key Question 1b sought to assess the cost, return-on-investment, or cost-effectiveness of QI strategies aimed to reduce HAI, but the strength of evidence addressing this question was insufficient. Methods of reporting costs or savings varied widely. No studies reported return-on-investment; only 1 reported net savings. This question needs greater investigation, given the importance of this information in guiding selection and implementation of QI strategies. More consistency in economic outcomes, greater methodological rigor in analyses, and more detailed reports of methods are needed to enable synthesis across studies.
Disability Outcomes | Research primarily treats disability as the main health concern, rarely as a complication. The review found few examples of research that viewed disability as a complicating condition rather than as the main condition of focus. This indicates that research adopting the perspective of disability as a complicating condition is still emerging; increased awareness is needed in the research and health care communities about newer models that view individuals with disabilities as living with disability, but not defined by it. Key questions remain unanswered. The review found no studies that addressed Key Questions 1b (modifiers of general population measures for use in disabled populations) or 1c (parameters for measuring processes related to basic service care access for people with disabilities). No studies used a mixed population of people with and without disabilities, highlighting a gap in the equity of health care research in this area. This likely relates to the predominant view within the research literature that disability is the central health concern for disabled people, rather than a complicating condition. However, the review authors cautioned that their results represent a sample of the literature on outcomes for people with disabilities, and more sensitive and specific search strategies might find studies missed by their broad search strategy.
Palliative Care | Little is known about palliative care in hospice or nursing homes. Although hospice is designed to focus on the needs of patients at the end of life, this review found very little research on palliative care interventions in this setting. Evidence about such interventions in nursing homes was also scant, even though many patients with advanced and serious illness receive care in this setting. Studies of cancer patients predominate. Few studies have focused on pediatric populations or specific disease groups beyond cancer. Studies focused on reducing disparities in palliative care were entirely lacking, despite evidence that disparities exist. The effectiveness of policy-focused interventions is unknown. Most research to date has investigated patient-focused, and to a lesser extent, provider-focused interventions. Research is needed that explores the impact of policy and regulatory interventions on patient-centered outcomes for palliative care.

Note: HAI = healthcare-associated infections; PCMH = patient-centered medical home; QI = quality improvement.

Table C-2 Messages for researchers

Topic | Take-Home Messages To Inform Future Research
Bundled Payment | Employ more robust evaluation designs. The evidence base for bundled payment will be strengthened if future studies employ more robust designs, such as difference-in-differences analyses with randomized intervention and control groups to reduce the risk of bias. Longer follow-up after implementation and reporting of outcomes at several time points will also improve the evidence base. Because evidence about the effects of bundled payment programs is urgently needed, the field will benefit if the results of longer term followup are reported separately so that publication of short-term results is not delayed. Finally, consider natural experiments or quasi-experimental research designs. Harmonize cost and quality outcomes. Studies varied widely in the cost and quality outcomes used to evaluate bundled payment programs, limiting the ability to synthesize results across studies. Use of more standardized measures will facilitate future evidence synthesis. Collaboratives of bundled payment evaluators could help facilitate the harmonization of measures across evaluations. Incorporate measures of program design and context into evaluations. Both quantitative and qualitative measures of design features and contextual factors should be incorporated into program evaluations to provide information about how to scale up programs for broader implementation. Program design features to measure include the definition of the bundle (i.e., number of providers, time window, specific services included and excluded), methods of limiting financial risk (e.g., risk adjustment and outlier payments), use of quality measurement, and methods for distributing payments among providers. Contextual factors to measure include the degree of integration in the delivery setting and the degree of financial pressure on participating delivery organizations. It will also be important to evaluate differential impacts on patient subgroups.
Patient-Centered Medical Home | Describe interventions in detail. Given such variety in how the PCMH model has been implemented, reports of PCMH interventions need to be described in detail. When possible, researchers ought to map elements of the intervention to the core PCMH components. This would facilitate evidence synthesis in the future and allow researchers to draw conclusions about elements of interventions and the PCMH model that are associated with key outcomes. Consider reporting complete details of PCMH interventions in separate publications. Address key knowledge gaps. We encourage investigators to adjust for clustering when appropriate, report meaningful quality indicators for chronic illness (both processes and clinical outcomes), and provide data related to the impact of PCMH on staff. We also encourage long-term followup of results. Outcomes examined in this report rarely had followup periods longer than 2 years. Furthermore, because PCMH has the potential to reduce heath disparities, evaluating effects in subgroups such as the socioeconomically disadvantaged will be important.
Disparities | Design studies that specifically address the effectiveness of QI interventions in reducing disparities. Evidence identified through this review stemmed from post hoc analyses, limiting the ability to link any observed changes in disparities with the specific QI intervention under study. To demonstrate an intervention's effectiveness in reducing disparities, future studies must first demonstrate the effectiveness of the intervention on the outcome(s) of interest (e.g., reducing blood pressure) using a nonintervention control group and must also demonstrate that the disparity in outcome between two patient groups was reduced in the intervention but not the comparison group. Investigate additional disparities. Most research to date about how to reduce health care disparities has focused on differences by racial and ethnic groups. More research is needed for additional types of health care disparities, such as disparities by socioeconomic status, insurance status, language preference, health literacy, age, sex, and geographic region. Furthermore, future studies should consider clustering of disparities (e.g., low-income minorities living in inner-city areas). Potential harms resulting from efforts to reduce disparities need exploration. No studies identified in this review addressed potential harms that might arise from efforts to reduce disparities through QI strategies. Future studies should look for evidence of harms.
Medication Adherence | Greater consistency in outcomes would strengthen the evidence base. Although medication adherence was an outcome in all studies reviewed, it was defined in myriad ways, making it difficult to synthesize evidence across studies. This and other study heterogeneity (e.g., included patient population, research design) precluded a quantitative meta-analysis. Although a single definition of medication adherence may not be applicable to all studies, use of a smaller number of adherence outcome definitions—ideally derived from consensus among researchers in this field—would facilitate comparative synthesis and strengthen the evidence base. More consistent terminology in describing interventions would also facilitate future evidence synthesis. Examine mechanisms of effectiveness. Investigations are needed into what characteristics of interventions, under what circumstances (patient population, disease, medications, settings), are associated with improved medication adherence and additional outcomes. More complete and specific descriptions of interventions would facilitate comparative synthesis to address this question, but well-designed, sufficiently powered studies focused specifically on addressing these questions are also needed. Theoretical models about the mechanisms through which such interventions operate would help guide this line of investigation. Include additional outcomes beyond medication adherence. This study found little evidence linking medication adherence with other outcomes, such as biomarkers, morbidity, mortality, quality of life, quality of care, patient satisfaction, health care utilization, or costs. Routinely including additional outcomes beyond adherence will provide further evidence on which to assess the relationship between adherence and key measures of health care quality and patient well-being.
Public Reporting | Specify reporting format and context in research publications. Information about the format of public reports (e.g., Web, print, email) and context of public reporting (e.g., patient population, users, decision type) ought to be included in research publications. To inform QI and implementation of public reporting, it will be particularly important to specify who used (or was expected to use) public reports, at what time, and for what purposes. Investigate the full range of public reporting programs. To date, a majority of studies of public reporting have focused on cardiac surgeries in just a few States and on nursing homes, reflecting only a portion of current and upcoming public reporting efforts. Future investigations should address the full range of current and developing public reporting programs. Investigations should also consider all potential users, motivations, and goals of public reporting when selecting evaluation criteria.
Healthcare-Associated Infections | Preintervention data are critical to strengthen the evidence base. Many studies contributed only low strength of evidence because they lacked preintervention data to enable analysis of temporal trends. Given the many factors that can affect infection rates and adherence to preventive interventions, such analysis is important for understanding the impact of specific QI strategies on those outcomes. Rather than simple before-after designs, studies can use an interrupted time series design (when controlled trials are not feasible), reporting data from at least 3 time points both before and after the intervention and conducting formal time series statistical analyses. Include contextual factors in reports; investigations of the role of context are needed. A key evidence gap identified by this review is the role that context plays in the outcome and success of QI strategies. At a minimum, reporting contextual factors will enable future reviews to better evaluate the role of context. Analyses that control for or evaluate the role of contextual factors will contribute much-needed evidence.
Disability Outcomes | More focused searches are needed for comprehensive review. The review authors caution that their results represent a sample of the literature on outcomes for people with disabilities. The broad scope of this review, which lacked search terms for particular outcomes measures, diseases, or disabilities, led to a search strategy that lacked both sensitivity and specificity. However, findings from this review may help guide future, more narrowly focused efforts. Measures identified in this review are a starting place for choosing research instruments. Although a detailed review of instruments sufficient to guide measure choice was beyond the scope of this review, the lists of measures, source articles, and databases and collaborative measure set development efforts identified in this review offer researchers a starting place for identifying instruments for use in their research. Measure selection would be greatly simplified in the future if a core set of outcomes measures were identified for use in research involving people with disabilities. The choice of outcomes and populations can contribute to disparities. People with disabilities often experience health care disparities, even while experiencing greater health care needs. Researchers contribute to these disparities when they systematically exclude people with disabilities from research studies or use measures that do not capture the full range of outcomes valued by people with disabilities. Researchers ought to be aware of these harms when designing studies and strive for multidisciplinary work that incorporates the perspectives of the medical, rehabilitation, and social services professions. Conduct research that is multidisciplinary and inclusive. Multidisciplinary research will help bridge silos and widen the range of measures used to include the full range of outcomes valued by people with disabilities.
Palliative Care | Include broader populations. This review found very little research in the hospice setting, among pediatric populations, or focusing on patient or caregiver distress. Much of the research to date has focused on the hospital intensive care unit setting and patients with cancer. Investigations are needed in additional settings—in particular, hospice and nursing homes—and additional patient populations, such as those with heart failure. Focus on key research gaps. Further development is needed of instruments to measure key patient-centered outcomes for this population, such as quality of life and caregiver burden. Other areas with robust instruments, such as pain, would benefit from standards for how the instruments are used and reported to better enable comparative synthesis across studies. Focus on recruitment and retention efforts to assure adequate sample sizes and describe interventions more fully in research publications. Pilot testing of outcomes measures to ensure that they are appropriate to the intervention under study would help strengthen many studies. Integrate QI into palliative care interventions. Few studies identified in this review used QI theory or methods such as collaboratives, Plan-Do-Study-Act cycles, or audit and feedback as part of the intervention. Applying knowledge and techniques from the robust and rapidly developing field of QI could strengthen the palliative care evidence base.

Note: PCMH = patient-centered medical home; QI = quality improvement.

Table C-3 Messages for research funders

Topic | Take-Home Messages To Inform Future Research
Bundled Payment | Encourage use of harmonized outcomes measures. Greater consistency is needed in the cost and quality outcomes used to evaluate bundled payment programs. Encouraging researchers to incorporate a set of key harmonized outcomes measures into evaluations would help facilitate future research. This set could be supplemented with additional program-specific measures as needed. Support evaluation of unintended consequences. Very few studies attempted to evaluate the effect of bundled payment programs beyond the specific setting or patient group targeted by the intervention. However, results from those studies suggest that bundling payments has broader impacts. Much more research is needed to explore unintended consequences of bundled payment programs.
Patient-Centered Medical Home | Continue investigating impacts on mortality. A single good-quality observational study found a mortality benefit at 1 year that was no longer significant at 2 years. This finding, along with nonsignificant findings of a good-quality randomized controlled trial with results in the direction of a mortality benefit and a poor-quality observational study that reported functional decline via a measure that includes mortality, points to the potential benefit of continuing to examine intensive PCMH-type interventions targeting frail seniors and the impact on mortality. Support or require more consistent nomenclature, outcomes, and measures related to PCMH. Within the next 2 years, the evidence base regarding PCMH is expected to more than double. An updated systematic review could be valuable, and researchers would be better able to leverage this evidence base if PCMH interventions were described more fully using common terminology. The evidence base would be further strengthened by more consistent use of measures of PCMH components and outcomes. The relative impact of PCMH components is key for applications. As the evidence base expands, analyses of the relative impact of PCMH components will be important for clarifying the key approaches for implementation. This knowledge could also inform certifying agencies' criteria for medical home practices. Clinical practices and policymakers also need better information on the financial context and implementation strategies required for successful spread and sustainability of the PCMH model.
Disparities | Support more robust study designs to facilitate conclusive research. Although complicated and therefore requiring more resources for support, studies that are designed to detect changes in both effectiveness outcomes and disparity between at least two groups of patients are extraordinarily important. Additional study is warranted on collaborative care and patient education strategies. Although limited, some evidence suggests that these strategies hold promise for reducing disparities. Further research—particularly using robust study designs—is needed to confirm these preliminary findings. Support research on a broader set of health care disparities. Most research to date about how to reduce health care disparities has focused on differences by racial and ethnic groups. More research is needed for additional types of health care disparities. Encourage researchers to explore potential harms. No studies identified in this review addressed potential harms that might arise from efforts to reduce disparities through QI strategies. Future studies should look for evidence of harms.
Medication Adherence | Medication adherence interventions are a “black box.” This review identified a myriad of interventions aimed at improving medication adherence. The interventions varied widely with respect to the key characteristics of target, agent, mode, intensity, duration, and components. Yet few studies examined how these characteristics impacted the effectiveness of the interventions with respect to medication adherence or other outcomes. This area is ripe for further investigation. Knowledge about specific characteristics that are most effective, and under what circumstances they are effective (which populations, diseases, medications, settings, etc.) will be of critical importance in guiding the design and implementation of QI interventions aimed at improving medication adherence, and potentially interventions with broader goals as well.
Public Reporting | Focus future research on advancing the science. Future research should leverage knowledge from past investigations and focus on developing the science rather than repeating past approaches that produced limited information. In conjunction with the producers of public reports and researchers, research sponsors need to identify key issues for the field and support investigations that target these areas. Focus attention on public reporting interventions and context. Rather than focusing exclusively on efficacy (does public reporting work?), future research should address effectiveness—for whom it works and in what situations. Furthermore, theoretical models are needed for how public reporting achieves its impacts, followed by research to test and refine those models. Support research on the full range of public reporting initiatives. Research is needed that expands investigation of public reporting beyond the much-studied settings of cardiac care (especially cardiac surgery) and nursing homes.
Healthcare-Associated Infections | Effective strategies outside the hospital setting are unknown. Research is needed on the effectiveness and cost-effectiveness of QI strategies employed in ambulatory surgery centers, dialysis centers, long-term care facilities, and other settings outside the hospital where patients are at risk for HAI. Much of the research to date has focused specifically on the hospital intensive care unit setting; investigations in other inpatient units may also be beneficial. Information on the impact of QI strategies on economic outcomes is urgently needed. In choosing a QI strategy and designing implementation, health delivery organization administrators and clinical leaders must consider costs, savings, and potential return-on-investment as well as anticipated effectiveness. This review found very little evidence relating to these economic outcomes. The available evidence was of limited utility due to inconsistency in choice of outcome, analytic methods, and research design. Additional research in this area is needed, particularly on return-on-investment and cost-effectiveness.
Disability Outcomes | More focused, narrow searches are needed in the future. As a starting place in tackling the topic of quality measurement for people with disabilities, this review was purposely broad in scope. However, this breadth resulted in search strategies that lacked sensitivity and specificity, yielding a sample rather than a comprehensive review of the available literature. The authors expect that literature could be identified to answer each of the Key Questions addressed by this review if more focused, narrow searches were undertaken. However, given the breadth of this field, several such reviews, each homing in on a separate area, would likely be needed. Further efforts are needed to assemble and assess measurement tools. This review identified several collaborative efforts to review large numbers of measurement tools, critically assess their applicability for research involving various disability populations, and assemble those tools into consensus-based core measure sets or databases. However, the efforts to date have focused either on narrow populations (e.g., patients who experienced stroke, frail elderly individuals, patients with spinal cord or traumatic brain injuries) or limited aspects of care (e.g., rehabilitation, developmental disability services). While these are important early steps, further work is needed to establish measure sets that address the full spectrum of QI and care coordination research related to people with disabilities. Further coordination among such efforts would also benefit the field. Support research that is inclusive and multidisciplinary. Researchers contribute to health care disparities for people with disabilities when they systematically exclude people with disabilities from research studies or use measures that do not capture the full range of outcomes valued by people with disabilities. Ideally, rather than isolating disabled populations in studies focusing exclusively on disability (the predominant disability-as-core-concern model) and excluding them from studies of the general population, future research incentives are needed for studies that include a mix of disabled and nondisabled people within study samples with appropriate adjustment for the disability as a complicating condition. Multidisciplinary research will help bridge silos and widen the range of measures used to include the full range of outcomes valued by people with disabilities.
Palliative Care | Key knowledge gaps require further research. Research funding is needed to support well-designed studies that evaluate QI and policy interventions, particularly in areas that are advancing rapidly in health care policy (e.g., audit and feedback and financial and regulatory interventions) but that have not been rigorously evaluated with regard to palliative care. Broadening research on palliative care interventions to a wider group of patients (current research being heavily focused on patients with cancer) and health care settings (beyond the intensive care unit) would yield valuable new knowledge. More research is needed to understand the effectiveness of both integrative and consultative palliative care models. This review found no studies that compared the two models directly.

Note: HAI = healthcare-associated infections; PCMH = patient-centered medical home; QI = quality improvement.

## Key Research Gaps

In addition to synthesizing evidence about a particular topic, systematic reviews provide valuable information about evidence gaps where further research is needed. This information can guide researchers and research funders in identifying key issues to address and developing research agendas. Table C-1 summarizes research gaps for each of the eight series topics.

## Messages for Researchers

The evidence base about what works and what does not work to improve health care quality is built on individual investigations of quality improvement interventions and publication of program evaluations. In their choice of questions, analytic approaches, and publication priorities, researchers help fill evidence gaps, replicate important findings, improve study quality, and develop theoretical models. Systematic reviews play a crucial role in informing these choices by developing critical questions, aggregating evidence across studies, identifying lessons learned from previous studies, and revealing knowledge gaps. Table C-2 summarizes key messages for researchers by topic.

## Messages for Research Funders

In supporting, and at times motivating, investigations, research funders also have a crucial role to play in advancing any given field. They shape research agendas through their role as gatekeepers of research support and can help advance the field by directing that funding toward the most robust study designs, most important research questions, and highest priority patient populations or care processes. They can also help encourage—or require—harmonization of measures across studies and development of theory to foster innovative approaches to improvement efforts. Systematic reviews provide a valuable tool to help research funders understand the questions and research tools that will help advance the field. The initial Closing the Quality Gap series cultivated such advancements, serving as a foundation for further evidence synthesis and continued evolution of the science of quality improvement, as demonstrated in this new series. Table C-3 summarizes key messages for research funders by topic.

## Reference

1 Ranji SR, Shetty K, Posley KA, Lewis R, Sundaram V, Galvin CM, Winston LG. Prevention of Healthcare-Associated Infections. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04(07)-0051-6. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007;6.