# Focus on Action: Key Messages for Improving Quality

In this appendix, we summarize how information learned through each review is useful for improving quality of health care. We organized this information according to key stakeholders because implications of the reviewed evidence may differ depending upon the audiences' perspective. These stakeholder groups are: patients or health care consumers and their caregivers, including patient advocacy organizations (Table B-1); clinicians and health care professionals, including physicians, nurses, pharmacists, social workers, and other clinical care providers (Table B-2); administrators of health delivery organizations, such as hospitals, outpatient clinics (primary or specialty care), and long-term care facilities (Table B-3); and policymakers (Table B-4). We present results for each potential audience separately.

Table B-1 Messages for improving quality for the patient/consumer/caregiver perspective

Topic | Take-Home Messages Motivating Potential Actions
Bundled Payment | The impact of bundled payment on quality of care is unknown. Implementing bundled payment programs generally showed small changes in quality measures, but the direction and magnitude of those effects varied within and across studies. Thus, it is unknown which aspects of care might be improved through bundled payments and which might experience a detrimental change. There was no evidence about whether bundled payment programs lead to providers avoiding high-risk patients.
Patient-Centered Medical Home | Small positive effects on patient experience were associated with PCMH. The PCMH model holds promise for improving the experiences of patients, and potentially for improving care processes. The review found evidence of moderate strength indicating that interventions meeting PCMH criteria were associated with small improvements in patient experiences, both on overall measures of patient satisfaction and on measures of patient-reported/patient-perceived level of care coordination.
Disparities | Very little research has focused on quality improvement strategies to reduce health care disparities. Further advocacy may be needed to encourage progress in this area.
Medication Adherence | Reducing out-of-pocket medication costs improved adherence. One of the most robust conclusions from this series underscores the important role that out-of-pocket costs play in medication adherence. This suggests the importance of assessing adequacy of pharmacy benefits in connection with adherence behaviors.
Public Reporting | Slight improvements in quality were associated with public reporting. Most studies of hospital-level public reporting found a decrease in mortality (19 studies, moderate strength of evidence), and studies of public reporting for health plans or long-term care facilities generally found improvements in outcomes such as pain, pressure ulcers, and satisfaction with care. It is unclear whether public reporting limits patient access. Evidence about the potential for health care providers to cherry-pick patients (thereby limiting access for sicker patients) was of low quality and yielded mixed results. One study found greater disparities between whites and blacks or Hispanics in receipt of coronary artery bypass graft surgery that persisted for 9 years following public reporting, but another study found that high-risk patients were more likely to see high-quality surgeons, contradicting the hypothesis that physicians might refuse to treat the highest risk patients to improve their performance on mortality and other patient outcomes measures. Public reporting had little impact on patient choice. Results across studies and settings consistently showed that patients and their families or representatives did not use public reports when selecting hospitals, clinicians, health plans, or nursing homes. The few studies reporting evidence for an effect of public reporting on patient choice did so only for a subgroup of patients. Evidence from 12 qualitative studies suggested that patients were often unaware that quality information was available through public reporting (4 studies); considered other factors such as travel distance; recommendations by family, friends, or doctors; and financial considerations to be more important in choosing a provider (7 studies); or did not find the quality measures included in the reports to be relevant or understandable (2 studies).
Healthcare-Associated Infections | Little evidence is available about patients' roles in reducing HAI. Patients and their caregivers may be able to encourage adherence to some preventive interventions if educated about good practices and empowered to voice concerns when their providers deviate from those practices. Yet this review found just 2 studies that examined patient education as a quality improvement strategy aimed at reducing HAI. Advocacy on behalf of patients may be needed to spur research in this area and further explore how the actions of patients and their caregivers may impact HAI rates or adherence to preventive interventions.
Disability Outcomes | There is a need to advocate for more inclusive research and engage in consensus efforts. Much of the literature included in this review views disability as the main health concern rather than as a complicating condition. None of the studies reviewed included a mixed population of people with and without disabilities. Advocacy from the community of people with disabilities may help encourage more inclusion of disabled people in research studies, further a view of disability as a complicating condition, and broaden the scope of outcomes measures used in disability research. Efforts to develop consensus-based core measure sets should incorporate input from individuals with disabilities.
Palliative Care | Interventions targeting continuity, coordination, and transitions of care improved patient and caregiver satisfaction. Although these interventions did not improve quality of life or symptoms, or decrease health care utilization (low strength of evidence), patients and their caregivers reported higher satisfaction with care for interventions focused on providing continuity of care, well-coordinated care, and facilitated transitions (moderate strength of evidence). Interventions targeting communication and decisionmaking did not improve patient satisfaction. Although these interventions decreased health care utilization (moderate strength of evidence), they did not improve patient or caregiver satisfaction (low strength of evidence), suggesting that this aspect of care may be less relevant to patients and their families. Little is known about interventions to decrease patient distress. There was only low strength of evidence that interventions targeting patient distress were effective: 2 of 7 RCTs showed significant improvement.

Note: HAI = healthcare-associated infections; PCMH = patient-centered medical home; RCT = randomized controlled trial.

Table B-2 Messages for improving quality for the clinician/health professional perspective

Topic | Take-Home Messages Motivating Potential Actions
Bundled Payment | Providers' response to bundled payment programs is largely unexplored. Several unintended consequences of bundled payment programs have been hypothesized, including providers avoiding high-risk patients, changing coding practices to maximize reimbursement for bundles, or moving services in time or location to qualify for separate reimbursement. This review found no studies that specifically sought to assess changes in provider behavior in response to bundled payment programs. However, several studies reported postimplementation changes that suggested some potential gaming. Some evidence demonstrated increased patient risk following implementation of bundled payment programs, but it is unknown whether this was due to changes in coding practices or to actual changes in the level of risk among the patient population. In addition, several programs that blended bundled payments with fee-for-service reimbursement reported greater use of services that generate higher reimbursement than before bundling.
Patient-Centered Medical Home | PCMH had small positive effects on staff experience. The PCMH model holds promise for improving the experiences of staff. This review found evidence of low strength that PCMH implementation was associated with improved staff experiences. However, none of the studies reporting information on staff experiences were conducted in pediatric practices. Two of the 3 were conducted in an older adult population. None of the studies reported outcomes more than approximately 2 years following the implementation of the intervention under study. Relatively few practices and few clinicians have been involved in these studies, and these practices may not be representative of the wider primary care practices in the United States. The extent of unanticipated consequences of implementation is not known. Unanticipated consequences such as increased provider burden, increased administrative time, and potential patient safety risks were not evaluated in the included studies. Various organizational learning and implementation strategies were used. Implementation of PCMH required significant restructuring for most primary care practices. Eight of 9 PCMH studies and 11 of 13 functional PCMH studies used a formal learning collaborative (e.g., lectures and training sessions) and/or collaborative planning sessions (e.g., team meetings) to make practices more consistent with PCMH. The most commonly used implementation strategy was audit and feedback at either the provider or practice level. Various financial models have supported PCMH implementation. Providers have concerns about costs for implementation and overall costs to the practice. Various strategies have been used to support PCMH implementation, including receipt of external study funding, capitation payments or salaried providers, or a hybrid approach.
Disparities | Evidence about effective QI strategies is inconclusive. The available evidence is insufficient to draw conclusions about QI strategies that are effective at reducing disparities. Before replicating any of the interventions included in this review, providers must consider whether the intervention is a good fit with their particular population, setting, and resources. No information is available about whether the interventions might lead to unintended harm.
Medication Adherence | Evidence for effectiveness varied considerably by patient condition. It is unlikely that any single medication adherence intervention will be effective for all patients with chronic conditions. This poses a challenge for providers seeking to improve adherence among all their patients, particularly in the primary care setting, where providers care for patients with a wide range of conditions. Providers may need to target improvement efforts toward patient populations with the greatest potential to benefit (poorest adherence and/or greatest potential for improvement with better adherence) and where there is moderate evidence of effective interventions. Interventions improved medication adherence in most vulnerable populations studied. Medication adherence improved for patients with major depression, severe depression, multiple chronic conditions, and depression with comorbid hypertension; black patients with coexisting depression and diabetes; and elderly patients with diabetes, hyperlipidemia, congestive heart failure, or hypertension. Choosing interventions for many patient populations will require extrapolation. This review found evidence regarding medication adherence interventions for a limited number of chronic conditions. Depression, asthma, diabetes, hypertension, and hyperlipidemia were the most commonly studied. Only a few studies, yielding low or insufficient evidence, were available for each of several additional conditions, such as glaucoma, myocardial infarction, musculoskeletal disorders, and multiple sclerosis. No information was available about the effectiveness of interventions for other chronic disease groups. Particularly in the primary care setting, clinicians must consider how to apply disease-specific evidence from this limited set of conditions to other patient groups. For example, interventions that appeared to improve medication adherence for hypertension and hyperlipidemia may help improve adherence with medication for other conditions that are asymptomatic or that aim to prevent long-term complications.
Public Reporting | Limited evidence suggests that individual clinicians make positive changes in response to public reporting. One study found that mortality rates declined following physician-level public reporting for cardiac surgery. Surgeons who stopped performing certain procedures after public reporting began were more likely to be poor performers (considered a positive change). Potential harms of public reporting were not confirmed. There was no evidence that public reporting leads to overdiagnosis or inappropriate prescribing (defensive medicine). Few physicians reported withdrawing from practice due to public reporting (1 study). Qualitative studies based on surveys and interviews revealed widespread mistrust of public reporting by physicians. Many cited concerns that public reporting would motivate clinicians to decline treatment to high-risk patients, but this review found only mixed evidence of this practice.
Healthcare-Associated Infections | Methods to prevent HAI are known, but reducing HAI rates requires that providers consistently use those methods. Although effective techniques to prevent HAI are well established, providers continue to lag in consistently applying these techniques, putting patients at unnecessary risk. Many QI strategies target provider behavior to increase their adherence to these evidence-based preventive interventions. Some combinations of QI strategies focusing on provider behavior work. Although widely used, organizational change and provider education alone do not appear to be sufficient to improve HAI rates or adherence to evidence-based preventive interventions. The review found moderate strength of evidence that supplementing these base strategies with additional approaches that focused on providers, namely, audit and feedback with or without provider reminder systems, led to improvements. Two studies of CLABSI reported that simulation-based provider education was more effective than traditional passive learning techniques, but more research is needed to confirm this result.
Disability Outcomes | Clinicians should be conscious of focus on disabilities relative to other health concerns. The review found few examples of research that viewed disability as a complicating condition. Rather, the predominant view treated disability as the primary health concern in disabled populations, particularly for research from the medical paradigm. When treating patients with disabilities, health care providers should be conscious of how much they focus on the disability itself relative to other health concerns, particularly with respect to preventive care and chronic disease management. At the same time, further training may be necessary to develop a greater understanding of how to address medical issues, manage chronic disease, or deliver preventive care in the context of physical or intellectual disabilities.
Palliative Care | Provider-centered interventions are not effective for continuity, coordination, and transitions. None of 6 studies that used solely provider-centered QI interventions (provider reminder systems, facilitated relay of clinical data to providers, or provider education) without additional patient-centered interventions to target this area demonstrated improved quality of life or satisfaction.

Note: CLABSI = central line-associated bloodstream infections; HAI = healthcare-associated infections; PCMH = patient-centered medical home; QI = quality improvement.

Table B-3 Messages for improving quality for the delivery organization perspective

Topic | Take-Home Messages Motivating Potential Actions
Bundled Payment | Bundled payment programs lower utilization slightly. Bundled payment was associated with between 5% and 15% lower utilization of services, in particular, shorter hospital length of stay. Utilization decreased to a greater extent for for-profit compared with not-for-profit providers. Although limited, some evidence suggested that bundled payment programs led to some care shifting to other settings.
Patient-Centered Medical Home | The jury is still out about the impact of PCMH interventions on clinical process-of-care outcomes. The review found evidence of low strength that PCMH may improve care processes, especially for preventive services. This is based on a combination of moderate evidence of an effect for preventive services and insufficient evidence to evaluate impacts on care for patients with chronic illness. High variability in PCMH implementation confounds research conclusions. Approaches to implementing the PCMH model varied greatly from one organization to another. While reflective of a rapidly innovating field, this variability limited the reviewers' ability to synthesize the research evidence and draw conclusions about what aspects of the PCMH model worked in what contexts and impacted which outcomes.
Disparities | Evidence about effective QI strategies is inconclusive. The available evidence is insufficient to draw conclusions about QI strategies that might be effective in reducing disparities. Before replicating any of the interventions included in this review, health delivery organizations must consider whether the intervention is a good fit with their particular population, setting, and resources. No information is available about whether the interventions might lead to unintended harm.
Medication Adherence | There is no single “silver bullet” for improving medication adherence. This review found a wide variety of interventions that successfully improved medication adherence. Most of these interventions were multifaceted; over half were aimed at multiple targets, and most had multiple components, including several with multiple delivery modes. The diversity of interventions that demonstrated effectiveness suggests that there are many potential pathways for improving adherence. Until further evidence becomes available about specific intervention characteristics associated with improvements under particular circumstances, organizations may be well served by experimenting with various interventions and refining their approach over time. The evidence base points to some starting places for choosing an intervention. The strongest evidence from this review points to several intervention approaches that were most often associated with success. Self-management approaches appeared to improve adherence with asthma medication, while case management improved adherence and symptoms for patients with depression. Pharmacist-led interventions improved both adherence and systolic blood pressure for patients with hypertension. Across conditions, consistent evidence supported the effectiveness of education, reminders, and pharmacist-led multicomponent interventions. Trials showing improvement in case management and educational interventions provided some evidence of improvement for other health outcomes as well. However, little is known about which intervention characteristics are likely to lead to success. Even interventions with a similar approach (e.g., education, case management) varied greatly with respect to their target, agent, mode, intensity, and duration. Little information was available about which of these characteristics are associated with effectiveness and under what circumstances. In the absence of such information, organizations interested in improving adherence among their patients may wish to seek out and learn from peer organizations that have already implemented medication adherence interventions. Participating in improvement collaboratives focused on this topic would provide opportunities for this type of sharing and iterative learning. Some amount of trial and error with iterative refinement will likely be necessary to achieve success.
Public Reporting | Delivery organizations make positive changes in response to public reporting. Although limited in number and setting, some studies reported that hospitals were more likely to offer new services, alter policies, and engage in QI activities following public reporting. Quality measures improved after public reporting for almost all HEDIS and CAHPS domains studied (5 studies). Evidence also supports improvements in other measures of quality, such as mortality (hospitals) and pain, pressure ulcers, and satisfaction with care (health plans, LTC facilities) following public reporting. Limited evidence exists of “gaming” of public reports in the LTC setting. One study reported that, to improve performance measures, nursing homes may readmit postacute care patients to the hospital just before Nursing Home Compare assessment. Moderate evidence suggests nursing homes may be motivated to change coding practices to improve performance. There was no evidence that health plans withdrew from the market or experienced declines in other unmeasured areas following public reporting. Few patients used public reports to select health care providers. Across settings, evidence consistently showed that patients, families, and their representatives rarely used publicly reported quality information to guide choice of health care providers. Qualitative studies indicated that public reports did not influence choice because of content (lack of relevant information), timing (not available at the time of decisionmaking), presentation, and awareness. Administrative actions seem to acknowledge this finding; in the LTC environment, administrative response to public reporting appeared to be motivated primarily by the expectation that those reports would influence professional referrals and the State survey process rather than patient and family selection of facilities.
Healthcare-Associated Infections | Moderate strength of evidence exists for audit and feedback with or without provider reminder systems as an effective QI strategy. Despite the great heterogeneity in studies, the review found evidence that, when combined with the base strategies of organizational change and/or provider education, using audit and feedback strategies alone or in combination with provider reminder systems improved infection rates and adherence to evidence-based preventive interventions. Evidence was insufficient that the base strategies alone improved these outcomes. Key questions remain unanswered. The above results were fairly consistent across the 4 categories of HAI (CLABSI, VAP, SSI, and CAUTI) but are applicable only to hospitals due to lack of evidence in other settings. Evidence was also lacking about contextual factors that may influence the effectiveness of these strategies and economic outcomes such as return-on-investment or net savings. Until such evidence becomes available, choice of QI strategy and implementation design will remain challenging.
Disability Outcomes | Access is a key concern for patients with disabilities. Among more than 100 measures identified in this review, the review authors found only 9—all for use in children—that assessed access to care. Yet patients with disabilities frequently experience access barriers such as transportation issues; difficulty navigating clinics, getting on exam tables or into imaging equipment; or challenges in communicating with providers. Access may be further limited by providers who are unfamiliar with how to treat medical conditions in the context of a particular disability. Health delivery organizations should be conscious of these access barriers and consider how to measure outcomes related to access for people with disabilities as part of QI efforts.
Palliative Care | Patient-focused QI interventions can be used to improve patient-centered outcomes. Six of 9 studies using patient-centered QI interventions to target continuity, coordination of care, and transitions showed a significant improvement in patient satisfaction and quality of life, while none of 6 studies using provider-centered QI interventions did so. A majority of interventions targeting pain were patient centered, and there was moderate evidence that pain-focused interventions improved outcomes related to pain. Some evidence supports both integrative and consultative palliative care models. Although evidence was analyzed only for interventions targeting communication and decisionmaking, some evidence supported the effectiveness of both integrative care models (4 of 8 studies showing improvement) and consultative care models (6 of 8 studies showing improvement).

Note: CAHPS = Consumer Assessment of Healthcare Providers and Systems; CAUTI = catheter-associated urinary tract infections; CLABSI = central line-associated bloodstream infections; HAI = healthcare-associated infections; HEDIS = Healthcare Effectiveness Data and Information Set; LTC = long-term care; PCMH = patient-centered medical home; QI = quality improvement; VAP = ventilator-associated pneumonia; SSI = surgical site infection.

Table B-4 Messages for improving quality for the policymaker perspective

Topic | Take-Home Messages Motivating Potential Actions
Bundled Payment | Bundled payments reduce spending and utilization slightly. The available evidence showed consistently that bundled payment programs resulted in small (≤10%) decreases in health care spending compared with cost-based or fee-for-service models. Bundled payment was also associated with between 5% and 15% lower utilization of services, in particular shorter hospital length of stay. The impact of bundled payment programs on quality of care is unclear. Quality measures often showed change following implementation of bundled payment programs, but the direction and magnitude of the difference varied both within studies (i.e., different quality measures evaluating a single program) and across studies (i.e., similar measures evaluating different programs). Potential unintended consequences of bundled payment programs remain unexplored. Studies rarely assessed unintended negative consequences of bundled payment, such as underutilization of effective services, avoiding high-risk patients, increasing the number of bundles reimbursed, changing coding practices to maximize reimbursement for bundles, or moving services in time or location to qualify for separate reimbursement. Studies of several programs reported that care shifted to other settings, suggesting that these programs may have broader impacts beyond the targeted settings and patient populations.
Patient-Centered Medical Home | Not much is conclusive yet regarding the impact of PCMH on clinical outcomes and care processes. There is overall evidence of low strength that PCMH may improve care processes, especially for preventive services. This is based on a combination of moderate evidence of an effect for preventive services and insufficient evidence to evaluate impacts on care for patients with chronic illness. PCMH as a QI approach is still in its infancy. From studies to date, the medical home is not a magic bullet to solve America's high cost of providing health care. Current evidence is insufficient to determine effects on clinical and most economic outcomes. The review found low strength of evidence that PCMH does not lead to uniformly lower utilization in two areas hypothesized to be affected: inpatient and emergency department utilization. Moreover, total costs were not consistently lowered in the reviewed studies. The amount of data that we have to bring to bear on this issue is expected to more than double in a few years.
Disparities | Additional study is warranted for collaborative care and patient education strategies. Although limited, some evidence suggested that these strategies hold promise for reducing disparities. Combining language and literacy concordance with patient education also holds promise. Although there was no direct evidence of their effectiveness in reducing health care disparities, in the absence of further information, these strategies might be a useful starting place for efforts to reduce disparities.
Medication Adherence | Decreasing out-of-pocket costs can improve medication adherence for patients with cardiovascular disease and diabetes. Although only 5 studies examined policy-level interventions, all found that reducing patients' out-of-pocket expenses for medications improved adherence, with the exception of adherence to inhaled corticosteroids (moderate strength of evidence). The mechanisms for reducing expenses varied across the studies, suggesting that how expenses are reduced is not as important as the reduction itself. Improved medication adherence does not necessarily mean improvement in other outcomes. Only a subset of interventions that showed improved medication adherence also showed improvement in other outcomes, such as biomarkers, morbidity, mortality, quality of life, quality of care, patient satisfaction, health care utilization, and costs.
Public Reporting | Current public reporting efforts are poorly matched to patient needs. Patients and their representatives rarely used publicly reported quality information as the basis for choosing a provider; qualitative research suggested patients did not have access to quality information when they needed it, outcomes reported were not relevant to them, or they did not understand the information as presented. Thus, current public reporting initiatives are unlikely to motivate change through market forces. Future public reporting efforts aimed at patients must be better tailored to patients' needs with respect to timing, accessibility, content, format, and mode. Health delivery organizations are more responsive to public reporting than patients or clinicians. Although mistrustful of public reporting, clinicians were somewhat responsive to publicly reported quality information; patients did not use information from public reporting. In contrast, health plans, hospitals, and especially nursing homes accepted public reporting and made changes to improve their performance. Except in the long-term care environment, little evidence was available about the motivation for these changes. Little evidence exists that public reporting leads to harm. Potential harms from public reporting have been the subject of many commentaries. Indeed, this review found that the volume of editorials and discussion about potential harms outweighed the volume of research investigating those harms. Most studies that investigated potential unintended negative consequences of public reporting did not confirm the potential harm. However, the horizon scan revealed ongoing research that might show some negative consequences of public reporting for nursing homes; these results were not yet published at the time the review was completed.
Healthcare-Associated Infections | Meaningful reductions in HAI rates are possible through QI. While questions remain about which QI strategies are most effective and cost-effective, particularly in different settings and contexts, the evidence shows potential for statistically and clinically meaningful reductions in HAI rates through various improvement strategies. Continued focus on this important area of patient safety, even in the absence of complete knowledge about improvement strategies, will likely lead to better patient care.
Disability Outcomes | Consensus around a core measure set is needed. The wide range of measures used in disability research limits the ability to make comparisons and synthesize research evidence across studies. Many similar concepts—such as health, quality of life, functioning, and patient experience—were assessed by the measures identified in this study, but different definitions, tools, and measurement scales were used. A core measure set for disability research would help facilitate comparative synthesis, although the desire for standardization must be balanced with the need for measures that are customized to particular groups, conditions, and research questions. Collaboration among researchers from the medical (curative), rehabilitation (restorative), and social services (supportive) perspectives is essential for advancing the field of disability research. Researchers' perspectives—whether trained and practicing in medicine, rehabilitation, or social services—have a profound impact on the ways in which care and life goals are conceptualized for people with disabilities. This influences and limits the types of outcomes selected for research, which has typically been performed in silos, with little cross-fertilization across professions. Multidisciplinary research will be essential to advance the field of disability research. It is crucial that any efforts to establish core measure sets for disability research include multiple perspectives. The choice of outcomes and populations can contribute to disparities. People with disabilities often experience health care disparities, even while experiencing greater health care needs. Researchers contribute to these disparities when they systematically exclude people with disabilities from research studies or use measures that do not capture the full range of outcomes valued by people with disabilities.
Palliative Care | Few intervention targets decrease health care utilization. Of the four key intervention target areas examined in this review (pain; continuity, coordination, and transitions; communication and decisionmaking; and distress), only communication and decisionmaking appeared to decrease health care utilization (moderate strength of evidence). The effectiveness of policy-focused interventions is unknown. Most research to date has investigated patient-focused, and to a lesser extent, provider-focused interventions. Research is needed to explore the impact of policy and regulatory interventions on patient-centered outcomes for palliative care.

Note: HAI = healthcare-associated infections; PCMH = patient-centered medical home; QI = quality improvement.

## Messages for the Patient/Consumer/Caregiver Perspective

Regardless of the focus or target of quality improvement (QI) interventions, as the consumers and recipients of health care, patients have a direct interest in the success or failure of QI initiatives. As they help patients navigate the health care system and strive for optimal health, family members and other informal caregivers also have an interest in the quality of care received by their loved ones. An inefficient, chaotic, or inequitable system also poses many challenges to caregivers, who all too often bear the burden of overcoming these barriers to high-quality care. Patient advocacy organizations play an important role in aggregating individual experiences—good and bad—into collective insights about strengths and weaknesses of the current health care system and ways in which the system might better meet patient needs. Thus, from the perspective of patients and their caregivers and representatives, evidence about QI initiatives is a valuable window into the health system and may signal leverage points where their actions, whether through individual discussions with providers or through collective advocacy, can help improve the quality of their care experience. Table B-1 summarizes key messages for this audience by topic.

## Messages for the Clinician/Health Professional Perspective

As the direct providers of care, clinicians and health professionals, including physicians, nurses, social workers, and pharmacists, play a crucial role in ensuring the quality of care patients receive. Whether initiating and directing QI activities or participating in QI programs initiated at an organization or systems level, health care professionals will benefit from an understanding of the effectiveness of various interventions and the ways in which those interventions interact with patient, organization, system, and market factors. Health care professionals can also benefit from an understanding of some of the potential harms hypothesized to arise from improvement strategies, such as changes in coding practices in response to information uses, avoiding high-risk patients or selecting only low-risk patients, or shifting care to suboptimal alternative settings in response to incentive changes. Table B-2 summarizes key messages for clinicians and other health professionals by topic.

## Messages for the Delivery Organization Perspective

Leaders of health delivery organizations play a crucial role in recognizing quality deficits within their organizations, identifying potential solutions, and driving QI activities. To guide these activities and make efficient use of limited improvement resources, these leaders need to know what works and what does not within a particular topic area. Table B-3 summarizes key messages for the health delivery organization perspective.

## Messages for the Policymaker Perspective

Like health delivery organization leaders, policymakers influence quality at a system level, identifying quality gaps ripe for improvement and developing programs aimed at closing those gaps. They, too, need information about which QI interventions are effective in what contexts, and the resource implications of various QI choices. Furthermore, in their focus on systems-level effects, policymakers are also best situated to initiate changes that improve quality by reducing negative consequences of fragmentation of care, addressing needs of vulnerable populations, and weighing potential harms from QI activities. Table B-4 summarizes key messages for the policymaker perspective.