# Topic Findings by Report

In this appendix, we provide a summary of the scope, methods, and findings from each of the eight reports in the Closing the Quality Gap: Revisiting the State of the Science Series. For each topic, we provide the working definition used to guide the review and summarize information about knowledge gaps addressed through each review, stakeholders that may be interested in the topic, Key Questions used to guide the reviews, and principal findings.

## 1 Effects of Bundled Payment Systems on Health Care Spending and Quality of Care

### What Is Bundled Payment?

The review authors defined “bundled payment” as a payment method in which payments to health care providers are related to the predetermined expected costs of a grouping, or “bundle,” of related health care services. This includes several different methods for aggregating services into a single unit of care for which a payment will be made. The review authors distinguished the following general aggregation methods and acknowledged that specific payment models may include some or all of these approaches:

- Aggregation of services longitudinally in time for an episode of care. The episode is defined to encompass services related to a health care treatment or condition taking place within a defined time window. For example, a single payment could include a surgical procedure and followup care.
- Aggregation of services across providers that may be practicing in different care settings. For example, a single payment could be made for inpatient hospital facility services and physician professional services during an inpatient stay.
- Warranties, payment arrangements by which payment for complications is aggregated into the unit of payment. Providers assume financial risk for the cost of care defects above a predetermined amount.

### What Is the Quality Gap Addressed by This Topic?

Although alternatives have been proposed and piloted, fee-for-service remains the predominant method of paying for health care in the United States. As health care costs have continued to rise dramatically, even while major quality gaps remain, interest has grown in alternative payment methods, including bundled payment programs, that aim to reduce health care spending while maintaining or improving quality of care. However, many questions remain about how bundled payment affects costs and quality of care, and whether it has unintended negative consequences. It is also unclear how contextual factors such as health delivery organization structure, for-profit status, or leadership impact the outcome of bundled payment programs.

### Who Is Interested in the Topic?

Given the widespread agreement that the current trend in growth of health care costs within the United States is unsustainable, this review provides valuable information to a broad group of audiences interested in bundled payments as one potential mechanism to reduce costs while also potentially improving quality. Those with an interest include policymakers, who need to understand the potential benefits and unintended consequences of bundled payment if considering it as alternative to fee-for-service payment. Payers, including the Centers for Medicare & Medicaid Services (CMS), will be interested in understanding the effect of bundled payments on health care spending, as well as its quality. In August 2011, CMS announced a large national bundled payment initiative. Providers and health care delivery organizations will be interested in understanding how their reimbursement might be affected by bundled payment programs and how such programs may drive changes in the way they deliver care. Patients and their representatives may also be interested, given the potential for changes (positive or negative) in the quality of care received through different payment models.

### What Evidence Are Stakeholders Seeking?

The Bundled Payment reviewers for the series sought to answer the following Key Questions:

- Bundled Payment Key Question 1: What does the evidence show on the effects of bundled payment versus usual (predominantly fee-for-service) payment on health care quality and spending measures?
- Bundled Payment Key Question 2: Does the evidence show differences in the effects of bundled payment systems by key design features?
- Bundled Payment Key Question 3: Does the evidence show differences in the effects of bundled payment systems by key contextual factors?

### What Is the Scope of the Review?

Focus: Hospitals, skilled nursing facilities, home health providers.

Outcomes analyzed: Change in health care spending per episode, utilization rates for specific services, provider cost/resource use to deliver episodes, quality of care, average risk/disease severity of patients treated.

Literature reviewed: The Bundled Payment reviewers searched for evidence published between January 1985 and January 2012 using the PubMed^®^ and Cochrane Library databases. The final review included 58 studies.

Analyses performed: The Bundled Payment reviewers summarized the evidence for the effects of bundled payment in comparison with usual payment methods. They did not conduct quantitative synthesis of results because they found relatively low similarity between studies along key dimensions such as study outcomes. They synthesized the results by bundled payment program, and then summarized these findings by Key Question.

### What Were the Key Findings?

Table A-1 summarizes the main results by Key Questions for this topic.

Table A-1 Bundled Payment key findings

Key Question 1: What does the evidence show on the effects of bundled payment versus usual (predominantly fee-for-service) payment on health care quality and spending measures?
Although of low strength due to heterogeneity and weaknesses in study design, the available evidence showed consistently that bundled payment programs resulted in small (≤10%) decreases in health care spending compared with cost-based or fee-for-service models. One review of the Medicare Heart Bypass Demonstration program found a 10% reduction in spending across 7 sites; 86% of savings resulted from lower negotiated reimbursement rates, 5% from lower postdischarge spending, and 9% from shifting care to lower cost hospitals. Across all reviewed studies, bundled payment was associated with between 5% and 15% lower utilization of services, in particular shorter hospital length of stay. The evidence for the impact of bundled payment programs on quality measures was less consistent. Changes in quality were generally small and inconsistent in direction and magnitude. This inconsistency was observed both within studies (different effects for different quality measures within a single study) and across studies (different effects for similar measures across different studies). Other than the impact on quality measures, studies rarely assessed unintended negative consequences of bundled payment programs, such as underutilization of effective services, avoiding high-risk patients, increasing the number of bundles reimbursed, changing coding practices to maximize reimbursement for bundles, or moving services in time or location to qualify for separate reimbursement. However, there was consistent evidence from multiple single-setting bundled payment programs that care shifted to other settings (i.e., from inpatient to outpatient care). Some evidence demonstrated increases in patient risk following implementation of bundled payment programs, but it is unknown whether this was due to changes in coding practices (i.e., shifting to higher risk codes) or to actual changes in the level of risk among the patient population. Several programs that blended bundled payments with fee-for-service reimbursement reported greater use of services that generate higher reimbursement after blending, such as providing additional rehabilitation time under the Medicare Skilled Nursing Facility Prospective Payment System (PPS) or providing more therapy visits per episode of care in the Medicare Home Health PPS.
Key Question 2: Does the evidence show differences in the effects of bundled payment systems by key design features?
The framework used to guide this review specified key bundled payment program design features of interest, including bundle components, payment methodology, level of payment, method for determining payment, risk-sharing properties, risk-adjustment methods, use of quality measurement, and distribution of payments among participating providers. No studies directly evaluated the effects of these design features on outcomes such as spending or quality measures. Heterogeneity in bundled payment interventions precluded the review authors from undertaking comparisons across studies to estimate such effects. Thus, the authors were unable to draw conclusions about the effects of bundled payment program design features on outcomes. Most programs reviewed focused on bundling for single-institution providers rather than bundling payments across settings. Bundle definitions were generally based on diagnoses. Few bundled payment programs integrated quality measurement or pay-for-performance into the payment mechanism.
Key Question 3: Does the evidence show differences in the effects of bundled payment systems by key contextual factors?
The framework used to guide this review specified key contextual factors that were hypothesized to impact the effectiveness of bundled payment programs, including the financial environment; incentives, charters, or missions of participating organizations; market characteristics; capabilities and goals of the participating organizations; the degree of integration among participating organizations; staff factors; and patient factors. However, few of these factors were evaluated by any of the identified studies. The reviewers found low strength of evidence that health care utilization declined to a greater extent when payment bundling was used to reimburse for-profit providers compared with not-for-profit providers. Likewise, the Medicare inpatient PPS program reported greater declines in utilization for hospitals that were under greater financial pressure (low strength of evidence). Although the influence of patient disease severity was examined by several studies, results were inconsistent (low strength of evidence).

## 2 The Patient-Centered Medical Home

### What Is a Patient-Centered Medical Home?

The review authors created an operational definition of a patient-centered medical home (PCMH) intervention based on the Agency for Healthcare Research and Quality definition of PCMH.25 To be considered, a PCMH intervention required:

1. Team-based care
2. At least two of four elements focused on how to improve the entire organization of care (enhanced access, coordinated care, comprehensiveness, systems-based approach to improving quality and safety)
3. A sustained partnership
4. An intervention that involves structural changes to the traditional practice

Studies that did not use the term “medical home” but met this definition were categorized as “functional PCMH” interventions.

### What Is the Quality Gap Addressed by This Topic?

The PCMH model aims to improve both care and patient experience across the full care continuum, from prevention through treatment of chronic and acute illness. It also holds promise for improving providers' experience and potentially reducing costs through greater efficiency. Widely endorsed by professional societies, payers (e.g., Medicare), and large health systems, PCMH-based interventions have been implemented in many different health care organizations. Studies of these interventions have shown that individual elements of the PCMH model are associated with improvements for some specific conditions and outcomes, but much remains unknown about whether implementation of a comprehensive PCMH improves care overall for the full population of patients served by a health care organization.

### Who Is Interested in the Topic?

The comprehensive nature of the PCMH model means that it has implications for a wide range of stakeholders, including health maintenance organizations, networks of Medicaid providers, community health centers, private integrated delivery systems, private practices, the U.S. Department of Veterans Affairs health care system, and parts of the Department of Defense military health care system. As its name implies, the PCMH model is centered on supporting the needs of patients. Thus, organizations representing patients, such as advocacy groups, large employers and other purchasers, and individual patients themselves may also be interested in this topic.

### What Evidence Are Stakeholders Seeking?

The PCMH reviewers for the series sought to answer the following Key Questions:

- PCMH Key Question 1: In published primary-care–based evaluations of comprehensive PCMH interventions, what are the effects of PCMH on patient and staff experiences, process of care, clinical outcomes, and economic outcomes?
  ○ 1a: Are specific PCMH components associated with greater effects on patient and staff experiences, process of care, clinical outcomes, and economic outcomes?
  ○ 1b: Is implementation of comprehensive PCMH associated with unintended consequences (e.g., decrease in levels of indicated care for nonpriority conditions) or other harms?
- PCMH Key Question 2: In published primary-care–based evaluations of comprehensive PCMH interventions, what individual PCMH components have been implemented?
- PCMH Key Question 3: In published primary-care–based evaluations of comprehensive PCMH interventions, what financial models and implementation strategies have been used to support uptake?
- PCMH Key Question 4: What primary-care–based studies evaluating the effects of comprehensive PCMH interventions on patient and staff experiences, process of care, clinical outcomes, or economic outcomes are currently underway? In these ongoing studies, what are the study designs, PCMH components, comparators, settings, financial models, and outcomes to be evaluated?

### What Is the Scope of the Review?

Population: Adults seeking care in general primary care and children with special heath care needs.

Outcomes analyzed: Patient experiences, staff experiences, process of care, clinical outcomes, and economic outcomes.

Literature reviewed: For Key Questions 1 through 3, the PCMH reviewers searched PubMed (through December 6, 2011), CINAHL^®^, and the CDSR (through March 30, 2011). For Key Question 4, they used the term “medical home” to search for ongoing or recently completed studies in the following databases: ClinicalTrials.gov, Commonwealth Fund, Robert Wood Johnson Foundation, and databases of federally funded studies—Agency for Healthcare Research and Quality, Centers for Disease Control and Prevention, Health Services Research Projects in Progress, National Institutes of Health (NIH) Reporter (NIH Research Portfolio Online), Health Resources and Services Administration, Veterans Affairs, and Department of Defense. All databases were searched using the enGrant Scientific^®^ interface. The final review included 51 articles representing 27 unique peer-reviewed studies.

Analyses performed:

- For Question 1 (effects of PCMH on patient and staff experiences, process of care, clinical outcomes, and economic outcomes), the PCMH reviewers identified the subset of studies using randomized controlled trial designs and employed a random-effects model to compute summary estimates of effect for two outcomes: hospitalizations and emergency department visits. They calculated summary estimates using Comprehensive Meta-Analysis software (Version 2; Biostat, Englewood, NJ) and reported summary risk ratios.
- For other outcomes, variation in the study populations, designs, and outcomes precluded quantitative analysis. Instead, to aid interpretation of the qualitative synthesis, the review authors computed effect sizes, represented as the standardized mean difference. This measure is useful when studies assess the same outcome using different measures or scales.26 The review authors presented beneficial effects as positive effect sizes.

### What Were the Key Findings?

Table A-2 summarizes the main results by Key Questions for this topic.

Table A-2 Patient-Centered Medical Home (PCMH) key findings

Key Question 1: What are effects of PCMH on outcomes (patient and staff experiences, process of care, clinical outcomes, economic outcomes)?
PCMH interventions had a small positive impact on patient experiences and small to moderate positive effects on the delivery of preventive care services (17 comparative studies, moderate strength of evidence). There was also a small to moderate impact on staff experiences (low strength of evidence). Among older adults, there was evidence that PCMH interventions reduced emergency department visits (risk ratio [RR], 0.81; 95% confidence interval [CI], 0.67 to 0.98) but not hospital admissions (RR, 0.96; 95% CI, 0.84 to 1.10) (low strength of evidence). However, there was no evidence for overall cost savings. Little evidence was available addressing unintended consequences of PCMH implementation.
Key Question 2: What individual PCMH components have been implemented?
Of 27 studies of PCMH interventions, 21 included all 7 major components of the PCMH model. Overall, studies used 51 different strategies to implement these core components. The most commonly addressed PCMH components were management of chronic illness, preventive care needs, and acute care needs; use of multidisciplinary teams; and coordination of care transitions. More than 75% of studies noted that new staff had been added during the intervention. Nearly all interventions included strategies to improve patient access, but studies varied widely in the choice of those strategies. The most widely used methods to improve health care quality and safety included identifying high-risk patients, using evidence-based clinical guidelines, monitoring performance, and using electronic health records. The number of studies reporting use of specific PCMH components can be found in Table 4 of the full report.27 Tables 16 and 18 show further detail on subcomponents of the PCMH model.
Key Question 3: What financial models and implementation strategies have been used to support uptake of PCMH?
Fewer than half (11 of 27) of included studies described aspects of their financial model. The payment models used to support PCMH implementation varied widely, including receipt of external study funding, capitation payments, enhanced fee-for-service, and a hybrid approach. Formal learning collaboratives and collaborative program planning forums were the most widely used organizational learning strategies (n = 19). More than half of studies used audit and feedback, usually with a quality improvement methodology, to implement PCMH. Table 20 of the full report summarizes financial, organizational learning, and implementation strategy types, and numbers of studies.27
Key Question 4: What primary-care–based studies evaluating the effects of comprehensive PCMH interventions on outcomes are currently underway? In these ongoing studies, what are the study designs, PCMH components, comparators, settings, financial models, and outcomes to be evaluated?
The horizon scan identified 31 ongoing PCMH studies, many performed in conjunction with payer organizations. These represented the wide range of payers (public and private), delivery networks, and geographic areas within the U.S. health care system. Most studies are expected to be completed in the next 2 years.

## 3 Quality Improvement Interventions To Address Health Disparities

### What Are Health Care Disparities?

Health care disparities are the differences or gaps in care experienced by one population compared with another. By definition, a disparity in health care quality or health outcomes is not due to differences in health care needs or preferences of the patient, but to other factors.14 Differences in health outcomes and their determinants are associated with certain social conditions such as socioeconomic status or education and demographic attributes such as race, ethnicity, sex, or age.

### What Is the Quality Gap Addressed by This Topic?

There is abundant evidence of health care disparities in the United States. A recent report from the Centers for Disease Control and Prevention (CDC) found that the rate of death due to coronary artery disease is substantially higher among black men and women than among white patients and that hypertension is more prevalent in the black population compared with other racial and ethnic groups in the United States. Furthermore, minority populations, in particular Native Americans, use tobacco at higher rates than whites, and rates of preventable hospitalization are higher among lower income patients.15 The 2011 National Healthcare Disparities Report found that disparities related to race, ethnicity, and socioeconomic status are widespread throughout the U.S. health care system; disparities are not decreasing over time; and lack of health care insurance is an important contributor to these disparities.16 The report recommended that particular attention be paid to disparities related to care for cancer, heart failure, and pneumonia. However, despite these well-known health disparities, evidence is lacking about how they might be reduced through quality improvement interventions.16 A 2006 systematic review found few studies that sought to reduce disparities through quality improvement approaches.17

### Who Is Interested in the Topic?

This review will primarily be of interest to researchers and research funders interested in health care disparities. It may also be of interest to health delivery organizations and policymakers interested in reducing disparities among patient populations. Advocacy organizations representing specific social groups experiencing disparities may also be interested in ways to reduce those gaps.

### What Evidence Are Stakeholders Seeking?

The Disparities reviewers for the series sought to answer the following Key Questions:

- Disparities Key Question 1: What evidence is available about the effectiveness of quality improvement strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?
- Disparities Key Question 2: What evidence is available about the harms related to quality improvement strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?

### What Is the Scope of the Review?

Population: Individuals receiving health care in the United States for a prespecified clinical condition.

Outcomes analyzed: Health outcomes (e.g., morbidity and mortality, indirect health outcomes such as blood pressure and hemoglobin A1c), process measures (e.g., proportion of patients treated according to clinical guidelines), changes in disparity, and harms (i.e., any negative impact of the intervention on the individual patients or the health care system).

Literature reviewed: The Disparities reviewers searched for evidence between 1983 and 2011 using the following databases: MEDLINE, CINAHL, Web of Science^®^ Social Science Index, and PsycINFO^®^. Non-U.S. studies were excluded due to important differences in health care system, disparity indicators, and groups experiencing disparities between the United States and other countries. The final review included 19 articles representing 14 studies of cancer, cardiovascular disease, depression, and diabetes. They targeted or described disparities associated with differences in race or ethnicity (n = 11 studies), socioeconomic status (n = 3), insurance status (n = 2), language (n = 2), health literacy (n = 1), and sex (n = 1). Eleven of the 14 studies were randomized controlled trials.

Analyses performed: The reviewers synthesized evidence by effect on particular disparities and by clinical condition.

### What Were the Key Findings?

Table A-3 summarizes the main results by Key Questions for this topic.

Table A-3 Disparities key findings

Key Question 1: What evidence is available about the effectiveness of quality improvement strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?
Disparities among racial and ethnic groups were the most frequently studied (11 of 14 studies). Only one of these studies demonstrated a reduction in disparity as a result of the quality improvement intervention.18 This study found that black but not white patients increased their hemoglobin A1c testing following a disease management and patient education program. An additional study of patient and provider education, self-management, and audit and feedback showed a reduced disparity in lipid testing between black and white patients with diabetes enrolled in Medicare, although the study design lacked a control group and therefore could not demonstrate whether this change was due to the intervention or other factors. Several other quality improvement interventions showed an amplified effect in minority populations, even though they did not reduce disparities. These included several patient education programs aimed at reducing blood pressure and a complex collaborative care model targeting providers caring for patients with depression. Both studies that examined language-based disparities focused on language concordance—providing health-related materials and support in patients' native or preferred language—and both found some evidence of greater intervention effects for non-English-speaking populations compared to English-speaking patients. Overall, the available evidence was not sufficient to draw clear conclusions about whether specific quality improvement strategies were effective at reducing health care disparities. However, some results from individual studies suggested the potential for effectiveness, pointing to strategies—specifically the collaborative care model and targeted patient education with language and health literacy concordance—that warrant further investigation.
Key Question 2: What evidence is available about the harms related to quality improvement strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?
This review found no information to address this Key Question.

## 4 Comparative Effectiveness of Medication Adherence Interventions

### What Is Medication Adherence?

Medication adherence is the extent to which patients take medication as prescribed by their health care providers.35 It is the patient's conformance with the provider's recommendation with respect to timing, dosage, and frequency of medication-taking during a prescribed length of time.36,37 Medication persistence, the act of continuing the treatment for the prescribed duration, is also important.37,38

### What Is the Quality Gap Addressed by This Topic?

Although pharmacotherapy is available to treat an astounding array of health conditions, even efficacious medications cannot be effective if not taken according to the timing, dosage, frequency, and duration prescribed by health care providers. Yet research suggests that between 20 and 30 percent of prescriptions are never filled and that half of medications prescribed to treat chronic disease are not taken appropriately.35,39-41 Direct costs of nonadherence are estimated to range between $100 and $289 billion in the United States,35,37,40-42 and strong evidence suggests that benefits attributable to improved self-management of chronic diseases could result in a cost-to-savings ratio of approximately 1:10.^43^ This review aimed to address both the efficacy and effectiveness of interventions designed to improve medication adherence for adults with chronic conditions. It updated a previous systematic review completed in 2008,^39^ further expanding the scope of that review to include interventions at the health system and policy levels. In addition, this review addressed evidence gaps by targeting studies of vulnerable populations (Key Question 4) and unintended consequences of medication adherence interventions (Key Question 5), and by including studies that reported medication adherence as an outcome, even if additional outcomes (e.g., mortality, morbidity) were not also reported.

### Who Is Interested in the Topic?

Given the potential cost-savings associated with effective pharmacotherapy, this review will be of interest to health plans and other payers such as large employers and Federal and State governments that pay for care through Medicare, Medicaid, the Veterans Health Administration, Indian Health Service, and Federal employee health care plans, among other programs. Key Question 2, which focuses on policy interventions to improve medication adherence, will be of particular interest to payers and policymakers, as will Key Questions 4 and 5, which focus on vulnerable populations and unintended consequences of medication adherence interventions. In the results of Key Question 1, health care providers and health delivery organization administrators that directly prescribe and provide medications will find information about methods to increase adherence among their patients through quality improvement interventions. This audience may also be interested in Key Question 3, which focuses on information about the effectiveness of various intervention characteristics, and Key Question 5. As the targets of efforts to improve medication adherence—and ultimately treatment for chronic disease—patients and their representatives may also have an interest in the results of this review. In addition, pharmacies and pharmaceutical companies that develop, license, produce, and sell prescription and over-the-counter medications will likely be interested in the effectiveness of medication adherence interventions.

### What Evidence Are Stakeholders Seeking?

The Medication Adherence reviewers for the series sought to answer the following Key Questions:

- Medication Adherence Key Question 1:
  ○ 1a: Among patients with chronic diseases with self-administered medication prescribed by a provider, what is the comparative effectiveness of interventions aimed at patients, providers, systems, and combinations of audiences in improving medication adherence?
  ○ 1b: Is improved medication adherence associated with improvement in patient outcomes?
- Medication Adherence Key Question 2:
  ○ 2a: Among patients with chronic diseases with self-administered medication prescribed by a provider, what is the comparative effectiveness of policy interventions in improving medication adherence?
  ○ 2b: Is improved medication adherence associated with improvement in patient outcomes?
- Medication Adherence Key Question 3:
  ○ 3a: How do medication-adherence intervention characteristics (e.g., mode of delivery, intervention target, intensity) vary?
  ○ 3b: To what extent do the effects of adherence interventions vary based on their characteristics?
- Medication Adherence Key Question 4: To what extent do the effects of adherence interventions vary based on differences in vulnerable populations?
- Medication Adherence Key Question 5: What unintended consequences are associated with interventions to improve medication adherence?

### What Is the Scope of the Review?

Population: Adults prescribed self-administered medication for secondary or tertiary prevention of chronic diseases in the United States, excluding patients with severe mental illness and substance abuse.

Outcomes analyzed: Biomarkers of clinical outcomes, clinical outcomes (e.g., mortality, morbidity), quality of life, patient satisfaction, health care utilization, quality of care, medication adherence, and adverse events.

Literature reviewed: The Medication Adherence reviewers searched evidence from 1994 to December 2011 using the following databases: MEDLINE, Cochrane Library, and the Cochrane Central Trials Registry. The final review included 68 articles that represent 62 studies (64 randomized controlled trials, 4 observational studies).

Analyses performed: All the data were qualitatively synthesized, and stratifications or categories were used for subgroup analyses. For Key Questions 1 and 2, the reviewers synthesized the evidence by clinical condition and type of intervention. For Key Questions 3, 4, and 5, they synthesized the evidence from all relevant studies included in Key Question 1 and Key Question 2.

### What Were the Key Findings?

Table A-4 summarizes the main results by Key Questions for this topic.

Table A-4 Medication Adherence key findings

Key Question 1a: Among patients with chronic diseases with self-administered medication prescribed by a provider, what is the comparative effectiveness of interventions aimed at patients, providers, systems, and combinations of audiences in improving medication adherence?
Evidence from 57 randomized controlled trials (RCTs) suggests that many different types of interventions have the potential to improve medication adherence. Across the 10 clinical condition groups examined, evidence was most extensive and consistent for the effectiveness of education and case management interventions. However, other strategies appeared to be more effective for specific conditions. For example, 6 of 8 studies in patients with asthma, chronic obstructive pulmonary disease, or reactive airway disease showed improvement in medication adherence in the intervention arm; 5 of those 6 used a self-management–focused intervention. In addition to type of intervention, the intensity seemed to impact effectiveness for some conditions. For patients with mild to moderate depression, high-intensity interventions that included face-to-face interactions and longer duration were effective at increasing medication adherence (moderate strength of evidence), while lower intensity, telephone-only interventions were not.
Key Question 1b: Is improved medication adherence associated with improvement in patient outcomes?
Only a subset of interventions that improved medication adherence also improved additional outcomes. These included disease-specific clinical outcomes such as blood pressure, hemoglobin A1c levels, pulmonary functioning, and depression symptoms. Other outcomes such as patient satisfaction, quality of life, or health care utilization were rarely examined; few studies demonstrated improvements in these outcomes, and results were often inconsistent between studies of a particular condition. The strength of evidence relating to outcomes other than medication adherence was generally insufficient.
Key Question 2: Among patients with chronic diseases with self-administered medication prescribed by a provider, what is the comparative effectiveness of policy interventions in improving medication adherence?
Five studies (1 RCT and 4 observational studies) evaluated the effects of policy-level interventions on medication adherence. All focused on the impact of out-of-pocket costs (i.e., copays and drug coverage) on medication adherence, including 1 study on Medicare Part D. Most studies focused on drugs for treating cardiovascular conditions (e.g., angiotensin-converting enzyme inhibitors; angiotensin receptor blockers; beta-blockers; statins; and medications to treat hyperlipidemia, hypertension, and heart failure), although additional medications were included in 2 studies. All 5 studies found better medication adherence in the intervention group for all medications except inhaled corticosteroids (moderate strength of evidence).
Key Question 2b: Is improved medication adherence associated with improvement in patient outcomes?
Only 1 of the 5 policy intervention studies examined outcomes other than medication adherence. This RCT found no difference in death from cardiovascular causes or total spending by the insurer (medication and nonmedication services), but found a 14% decrease in the risk of first vascular event and a 26% decrease in total patient spending in the group with a reduced medication copay. However, the strength of this evidence was judged to be insufficient because it was based on a single study.
Key Question 3a: How do medication-adherence intervention characteristics (e.g., mode of delivery, intervention target, intensity) vary?
Most studies provided information about 6 key intervention characteristics: the target, agent, and mode of the intervention, in addition to its intensity (total time and frequency), duration, and components. However, differences in how this information was presented limited the ability to make comparisons across studies. The most frequent targets of adherence interventions were patients (40%); a combination of patients, providers, and systems (23%); and a combination of patients and systems (19%). Approximately half of adherence interventions were delivered by a pharmacist (19%), physician (11%), or nurse (16%) (agent), and half involved face-to-face contact (mode). Details of intensity (frequency and duration of interaction) were lacking or incomplete from more than half of the studies reviewed. More than three-quarters (77%) of interventions included a knowledge-based component, and nearly half (44%) also included an awareness-based component. Awareness was almost always combined with knowledge components. Few interventions used stress management (3%) or social influence (3%) components, and none used contingent rewards.
Key Question 3b: To what extent do the effects of adherence interventions vary based on their characteristics?
Only 4 RCTs directly compared different interventions to assess their effects on medication adherence. All used patient-focused interventions, although 1 also included provider- and system-level components in the intervention. There was low strength of evidence that shared decisionmaking (patient and provider together) improved medication adherence and pulmonary function (among patients with asthma) but not symptoms, quality of life, or health care utilization, compared with clinical decisionmaking (provider only). There was insufficient evidence about the effect of intervention agent (e.g., patient, physician, nurse, research staff), mode (e.g., telephone vs. video reminders), or intensity (e.g., frequency and duration of intervention interactions) on medication adherence.
Key Question 4: To what extent do the effects of adherence interventions vary based on differences in vulnerable populations?
In general, interventions had a positive impact on medication adherence for most vulnerable populations examined (low strength of evidence from 15 studies). Specifically, these populations were patients with major depression, severe depression, multiple chronic conditions, or depression with comorbid hypertension, or black patients with coexisting depression and diabetes. Elderly patients with diabetes, hyperlipidemia, congestive heart failure, or hypertension also had improved medication adherence. There was insufficient evidence for improvement following the intervention for patients with coexisting depression and HIV, coexisting hypertension and diabetes, or coexisting depression and diabetes (except for black patients in the latter group, whose adherence improved). Evidence was mixed about the impact of interventions on patients in rural communities (insufficient evidence). These studies were very heterogeneous with respect to population, intervention, and definition of medication adherence.
Key Question 5: What unintended consequences are associated with interventions to improve medication adherence?
Only 3 studies were applicable to this question, and they differed greatly with respect to adverse events evaluated, interventions, diseases, and medications included in the studies. Evidence was insufficient to draw conclusions about potential unintended consequences associated with medication adherence interventions. None of the studies reported significantly higher adverse events in the intervention group.

## 5 Public Reporting as a Quality Improvement Strategy

### What Is Public Reporting?

Public reporting is data, publicly available or available to a broad audience free of charge or at a nominal cost, about a health care structure, process, or outcome at any provider level (individual clinician, group, or organizations such as hospitals and nursing facilities) or at the health plan level. While public reporting is generally understood to involve comparative data across providers, the authors of this review adopted a broader approach to include findings in which one provider is compared with a national/regional data report on performance for which there are accepted standards or best practices.

### What Is the Quality Gap Addressed by this Topic?

Public reporting is an important way to motivate delivery of high-quality care. In particular, it provides incentives for engaging in quality improvement activities.8,9 Public reporting initiatives have expanded greatly in recent years, as has the availability of health data and the ability to aggregate it in meaningful ways.10 The amount of publicly reported health care quality data is likely to continue to increase substantially in tandem with a growing focus within the U.S. health care system on transparency and patient-centered care. Furthermore, previous systematic reviews of public reporting have not included studies of quality data within the long-term care (LTC) setting, which is now the focus of major national public reporting initiatives, in particular for nursing homes.11-13

### Who Is Interested in the Topic?

Public reporting creates incentives for improvements in care and choice of health care providers for a variety of stakeholders, all of whom may find this report of interest. Consumers—patients, families, patient advocates, and health care purchasers such as employers—may use publicly reported quality information when making decisions about where to obtain care. Public reporting may also provide essential information to individual health care providers (e.g., clinicians) or health care delivery organizations (e.g., hospitals, long-term care facilities, health plans) that wish to attract new patients or members, avoid the loss of existing ones, uphold commitments to provide high-quality care, and protect or improve their reputation among peers. Federal and State government agencies, community quality collaboratives, and other health care quality organizations may find that this report informs their use of public reporting as a strategy to improve care at a system level.

### What Evidence Are Stakeholders Seeking?

To provide key information to these stakeholders and fill existing evidence gaps about public reporting, the Public Reporting reviewers for the series sought to answer the following Key Questions:

- Public Reporting Key Question 1: Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)?
- Public Reporting Key Question 2: What harms result from public reporting?
- Public Reporting Key Question 3: Does public reporting lead to change in health care delivery structures or processes (at levels of individual providers, groups, or organizations such as health plans, hospitals, and nursing facilities)?
- Public Reporting Key Question 4: Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?
- Public Reporting Key Question 5: What characteristics of public reporting increase its impact on quality of care?
- Public Reporting Key Question 6: What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?

### What Is the Scope of the Review?

Focus: Public reporting of hospitals, long-term care facilities, health plans, and individual clinicians.

Outcomes analyzed: Health care quality (system structures or processes, or patient outcomes), unintended negative consequences (harms), changes in health care delivery structures or processes, changes in patient or purchaser behavior.

Literature reviewed: The Public Reporting reviewers searched for evidence published between January 1980 and December 31, 2011, using the following databases: MEDLINE, EMBASE^®^, EconLit, PsychINFO^®^ Business Source^®^ Premier, Cumulative Index of Nursing and Allied Health Literature (CINAHL^®^), Public Affairs Information Services (PAIS), the Cochrane Database of Systematic Reviews (CDSR), the Cochrane Effective Practice and Organization of Care Group (EPOC) Register of Studies, Database of Abstracts of Reviews of Effects (DARE), National Health Service Economic Evaluation Database (NHS EED), Health Economic Evaluations Database (HEED), the Grey Literature Report database (maintained by the New York Academy of Medicine), and AARP Ageline. The final review included 205 articles comprising 198 studies, of which 97 (49 percent) were quantitative and 101 (51 percent) were qualitative.

Analyses performed: The heterogeneity of outcomes precluded the review authors from performing a formal quantitative meta-analysis. To synthesize evidence, they separated studies into four groups according to the type of health care entity for which data were publicly reported:

- Hospitals (further divided into cardiac and noncardiac inpatient care)
- Individual clinicians or outpatient group practices
- Health plans
- Long-term care services (predominantly nursing homes)

The review authors chose this grouping because public reporting has a different history in each of these settings, and the content and presentation of public reports differ for each of these settings. They reported results for each Key Question separately for each of these four groups of studies.

### What Were the Key Findings?

Table A-5 summarizes the main results by Key Questions for this topic.

Table A-5 Public Reporting key findings

Key Question 1: Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)?
Most studies of hospital-level public reporting found a decrease in mortality (the most commonly studied outcome) compared with no reporting, although some questions remained about the appropriateness of comparisons in some studies (19 studies, moderate strength of evidence). Analysis of hospitals was divided into those that focused on cardiac care and those that did not. Among cardiac-focused articles, results were mixed, with 8 studies reporting improvements (decreases) in mortality with public reporting, 4 finding no difference, and 1 study reporting increased mortality with public reporting. Ten of 11 studies on public reporting for noncardiac hospital care found slight improvements in quality. Studies of public reporting for health plans or long-term care facilities generally found improvements in quality of care in the reporting group as measured by outcomes such as pain, pressure ulcers, and satisfaction with care. The impact of public reporting on health care quality varied in some studies depending on the health plan or population subgroup. At the health plan level, public reporting of most Healthcare Effectiveness Data and Information Set (HEDIS) and CAHPS domains was associated with improvements in quality measures (5 studies).
Key Question 2: What harms result from public reporting?
Although harm is frequently cited as a concern, the limited research on unintended negative consequences from public reporting does not generally confirm the potential harm. On balance, evidence that public reporting does not lead to unintended negative consequences outweighed evidence of its harms. Although frequently examined (12 studies), evidence about the impact of public reporting on patient access (e.g., cream-skimming, cherry-picking) was of low quality and yielded mixed results. Some studies of long-term care (LTC) found evidence that public reporting created incentives for changing coding practices and readmitting patients to the hospital just before assessment for Nursing Home Compare. This was the most serious harm identified among the studies reviewed. No evidence was found that public reporting was associated with surgeons or health care organizations withdrawing from the market or with declines in the quality of unmeasured aspects of care (crowding out) (5 studies, moderate strength of evidence).
Key Question 3: Does public reporting lead to change in health care delivery structures or processes (at levels of individual providers, groups, or organizations)?
Among the studies reviewed, both individual clinicians and health care organizations responded positively to public reporting, offering new services, changing policies, and increasing quality improvement activities (10 studies, moderate strength of evidence). One study found that poor-performing surgeons were more likely to leave surgical practice after public reporting (considered a positive outcome). In the LTC environment, nursing home administrators invested more in clinical care following public reporting (1 study), and those that took action following public reports demonstrated improvements in quality measures (1 study). Nursing home administrative actions in response to public reporting appeared to be motivated primarily by the expectation that those reports would influence professional referrals and the State survey process rather than patient and family selection of facilities.
Key Question 4: Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?
Results across studies and settings consistently showed that patients and their families or representatives did not use public reports when selecting health care providers: 10 studies found no or only weak evidence that public reporting influenced patient choice of provider. The few studies that reported evidence for an effect of public reporting on patient choice did so only for a subgroup of patients. Studies of contracting patterns found that public reports played only a minor role in guiding selection of providers (47 studies, moderate strength of evidence).
Key Question 5: What characteristics of public reporting increase its impact on quality of care?
The review found very little evidence to address this Key Question; quantitative evidence was particularly lacking. Only 2 studies, both on public reporting of individual clinicians, examined the impact of report characteristics on quality of care. One study of poor quality found that use of email vs. mail influenced use of public reports, while message tone (risks vs. benefits) did not. Another study reported that information in public reports remained accurate and useful even when delayed by several years before release. No studies addressed this Key Question for hospitals, LTC, or health plans.
Key Question 6: What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?
Strong evidence suggests that public reporting leads to quality improvements more readily in competitive markets (7 studies, high strength of evidence). Providers and health care organizations with poor initial performance were more likely to make improvements following public reporting than those with better initial performance (5 studies, high strength of evidence). Characteristics of nursing homes did not predict how facilities responded to publicly reported quality information (6 studies, low strength of evidence), but some patient characteristics (i.e., age, health needs, insurance coverage) impacted use of publicly reported quality information when making health care choices. However, the strength of evidence for these 3 studies of LTC public reporting was low.

## 6 Prevention of Healthcare-Associated Infections

### What Are Healthcare-Associated Infections (HAI)?

The CDC defines a healthcare-associated infection as: “a localized or systemic condition resulting from an adverse reaction to the presence of an infectious agent(s) or its toxin(s). There must be no evidence that the infection was present or incubating at the time of admission to the acute care setting.”28

### What Is a Preventive Intervention?

For the purposes of this review, a preventive intervention is a specific infection-control practice that has been demonstrated to reduce the incidence of HAI. An example would be using maximal sterile barrier precautions when inserting a central line.

### What Is the Quality Gap Addressed by This Topic?

HAI are widespread and costly in the U.S. health care system. According to an estimate by the CDC, in 2002 there were 1.7 million HAI and 99,000 HAI-associated deaths in hospitals. More than 80 percent of these HAI were caused by the four most common categories: central line-associated bloodstream infections (CLABSI) (14 percent), ventilator-associated pneumonia (VAP) (15 percent), surgical site infections (SSI) (22 percent), and catheter-associated urinary tract infections (CAUTI) (32 percent).29 Evidence-based strategies to eliminate HAI are known and endorsed by many professional societies,32 but these preventive interventions have not been fully implemented into clinical practice throughout the United States. The 2003 Institute of Medicine report on priority areas included adherence to evidence-based HAI preventive interventions among its 20 priority conditions for which a gap remains between knowledge of the topic and integration of that knowledge into the clinical setting.2 Information is needed about quality improvement strategies that lead to effective adoption of these preventive interventions. In light of much recent research on this topic, this review updates a previous review published in 2007,^31^ and expands that review to include additional settings (e.g., ambulatory surgical centers, dialysis centers, and long-term care facilities) in addition to hospitals.

### Who Is Interested in the Topic?

Knowledge of the costs, benefits, effectiveness, and trade-offs of quality improvement strategies aimed at reducing HAI is essential when designing, selecting, and implementing improvement programs. This review will be of interest to individuals or organizations that wish to reduce HAI through quality improvement initiatives. This includes policymakers seeking to make measurable improvements in this national priority area; administrators of hospitals, ambulatory surgical centers, dialysis centers, long-term care facilities, and other health care organizations concerned about HAI among their patient population; and payers that wish to reduce the incidence of HAI, which account for substantial health care costs. 32

### What Evidence Are Stakeholders Seeking?

The HAI reviewers for the Series sought to answer the following Key Questions:

- HAI Key Question 1: Which quality improvement strategies are effective in reducing the following HAI: central line-associated bloodstream infections, ventilator-associated pneumonia, surgical site infections, and catheter-associated urinary tract infections?
  ○ 1a: Which quality improvement strategies are effective in increasing adherence to evidence-based preventive interventions for the four HAI listed above?
  ○ 1b: What is the cost, return-on-investment, or cost-effectiveness for health care providers, and society as a whole, of quality improvement strategies to reduce these HAI?
  ○ 1c: Which factors are associated with the effectiveness of quality improvement strategies?
- HAI Key Question 2: What is the impact of health care context on the effectiveness of quality improvement strategies, including reducing infections and increasing adherence to preventive interventions?

### What Is the Scope of the Review?

Population: Patients at risk for CLABSI, VAP, SSI, or CAUTI in hospitals, ambulatory surgery centers, dialysis centers, or long-term care facilities.

Outcomes analyzed: Adherence to various preventive interventions, change in infection rates, costs, and return-on-investment.

Literature reviewed: The HAI reviewers searched for evidence published between January 2006 and January 2012 using the following databases: MEDLINE, CINAHL, and EMBASE^®^. The final review included 152 articles.

Analyses performed: The articles were divided into two categories: those with infection rates or adherence rates that were adjusted for confounding or temporal trends and those that adjusted for neither. Results for each category were synthesized separately in a qualitative manner.

### What Were the Key Findings?

Table A-6 summarizes the main results by Key Questions for this topic.

Table A-6 Healthcare-Associated Infections (HAI) key findings

Key Questions 1 and 1a: Which quality improvement strategies are effective in reducing HAI—central line-associated bloodstream infections (CLABSI), ventilator-associated pneumonia (VAP), surgical site infections (SSI), or catheter-associated urinary tract infections (CAUTI)—and improving adherence to evidence-based preventive interventions?
A majority of included studies (90%) used organizational change and/or provider education as a quality improvement strategy. There was insufficient evidence that these strategies (alone or in combination) improved infection rates or adherence. Because they were so common, all further analyses considered the effectiveness of adding additional strategies to these “base strategies.” The review found moderate evidence that both infection rates and adherence to evidence-based preventive interventions improved when audit and feedback combined with provider reminder systems, or audit and feedback alone, were employed in combination with the base strategies. There was also some evidence that provider reminder systems alone improved adherence and infection rates (low strength of evidence). In general, these results were consistent across the 4 HAI categories. Results for each of the four HAI categories are reported in Table 47 of the full report.44 Few studies reported on the effectiveness of financial incentives, regulation, or policy (n = 2) or patient education (n = 2) as additional quality improvement strategies. Although the review was intended to capture evidence from many different settings, no studies were found regarding effectiveness in settings other than the hospital.
Key Question 1b: What is the cost, return-on-investment, or cost-effectiveness for health care providers, and society as a whole, of quality improvement strategies to reduce these HAI?
Overall, the strength of evidence addressing this question was judged to be insufficient due to a limited number of studies reporting economic outcomes (n = 14, of which 10 adjusted for confounding or secular trends), variation in the quality improvement initiatives used in those studies, and heterogeneity in economic metrics and analysis techniques used. Furthermore, no studies evaluated return-on-investment and only 1 study evaluated net savings of quality improvement strategies to reduce HAI. One study of audit and feedback combined with organizational change and provider and patient education reported that average intervention costs among 6 randomly selected hospitals were $3,375 per infection avoided, and 47.9 infections were avoided per hospital during each year of the study.33 Another study of the same combination of strategies estimated more than $1.9 million in annual savings by reducing CLABSI infections by 43 cases per year.34
Key Question 1c: Which factors are associated with the effectiveness of quality improvement strategies?
The main factor analyzed in this review was the type of quality improvement strategy (e.g., audit and feedback, provider reminder system) employed. There was moderate evidence that combining audit and feedback and provider reminder systems with the base strategies of organizational change and provider education reduced infection rates (with 5 of 7 studies finding significant improvements) and increased adherence to evidence-based preventive interventions (22 of 35 studies). Moderate evidence also suggested that infection rates and adherence rates improved when using audit and feedback alone or in combination with the base strategies (11 studies). Evidence was mixed regarding use of provider reminder systems alone or in combination with the base strategies; all adherence rates improved among the 9 studies included in this analysis, but only 5 of the 9 showed an improvement in infection rates (low strength of evidence). Neither of the 2 high-quality studies showed reduced infection rates. These conclusions were limited to CAUTI due to limited data for the other categories of HAI. There was insufficient evidence to assess the impact of the base strategies alone. The review authors were unable to address additional factors such as duration of intervention, setting, or staffing due to limitations in the available literature.
Key Question 2: What is the impact of health care context on the effectiveness of quality improvement strategies, including reducing infections and increasing adherence to preventive interventions?
The review authors found great variability in what, if any, contextual factors were reported. Nearly all (97%) of the 72 studies analyzed reported at least 1 of 7 contextual factors examined in this review; 61 percent reported at least 3 factors. The 3 most commonly reported contextual factors were availability of implementation materials, followed by changes in responsibilities at the unit level and leadership at the unit level. There was also great variability in how contextual factors were used; some authors attempted to control for contextual factors in analyses, while others merely discussed them. Thus, the review authors did not attempt to synthesize evidence about how contextual factors impacted HAI rates or adherence to preventive interventions.

## 7 Measuring Outcomes of Care for People With Disabilities

### How Was Disability Defined for This Review?

For the purposes of this review, people with disabilities were defined as those with physical, sensory, and/or mental health conditions that can be associated with a decrease in functioning in such day-to-day activities as bathing, walking, doing everyday chores, and/or engaging in work or social activities.1

### What Is the Quality Gap Addressed by This Topic?

The Agency for Healthcare Research and Quality identified people with disabilities as a priority population as part of their charge to continuously assess progress toward health care quality and to update the list of national priority areas identified in 2003 by the Institute of Medicine.2 Disabilities, in particular those that are developmental or acquired, can complicate provision of health care. Challenges include exacerbation or complication of medical problems by the disability or related medical, psychological, economic, and social problems or difficulties in management of medical conditions due to the particular characteristics of the disability. Furthermore, providing high-quality care requires that medical care be coordinated with a potentially wide range of social and support services. Outcomes measures are needed that can assess the effectiveness of quality improvement interventions (whether targeted to individuals with disabilities or to broader populations) while accounting for the special challenges in caring for people with disabilities. Measuring the effectiveness of care coordination programs will be further strengthened by including process measures that can detect coordination among medical and social services.

Although some efforts have been made to measure health care quality for individuals with disabilities,1,3 there is as yet no consensus about whether outcomes related to medical care can be assessed in similar ways for patients with and without disabilities. Furthermore, methods for adjusting general population outcomes measures for use in disability populations, or in broader populations that include individuals with disabilities, have varied.

### Who Is Interested in the Topic?

This review aimed to lay the foundation for a shared understanding among researchers, clinicians, and policymakers about issues related to quality measurement for people with disabilities. It will be of interest to anyone who wishes to evaluate the effectiveness of quality improvement interventions that target care for people with disabilities or that target broader populations that include people with disabilities. It will also be of interest to State and Federal agencies with a responsibility for supporting the health and well-being of people with disabilities through medical coverage and social support programs (e.g., Medicaid programs). In addition, it may be of interest to organizations that advocate for people with disabilities, who will be better able to assess and address quality gaps when robust outcomes measures applicable to disability populations are available.

### What Evidence Are Stakeholders Seeking?

The Disability Outcomes reviewers for the series sought to answer the following Key Questions:

- Disability Outcomes Key Question 1. How are outcomes assessed for people with disabilities living in the community in terms of basic medical service needs?
  ○ 1a: What general population outcomes have been validated on and/or adjusted to accommodate disabled populations?
  ○ 1b: What types of modifiers or case-mix adjusters have been used with the general population outcomes to recognize the special circumstances of people with disabilities?
  ○ 1c: What are key parameters for measuring processes related to basic service care access for people with disabilities?
- Disability Outcomes Key Question 2: What measures have been used to assess effectiveness of care for people with disabilities living in the community in the context of coordination among health providers?
- Disability Outcomes Key Question 3: What measures have been used to assess effectiveness of care for people with disabilities living in the community in the context of coordination between community organizations and health providers?

### What Is the Scope of the Review?

Population: Community-dwelling people of all ages who were diagnosed with and/or documented to have physical and cognitive disabilities. Individuals undergoing vocational rehabilitation only or with severe and persistent mental illness as the primary disabling condition were not included within the scope of this review.

Settings: Outpatient health; home- and community-based services.

Scope: To keep the project scope feasible, the review authors focused on measures that could be used to assess either (1) interventions aimed at specific medical needs for people with disabilities or (2) comprehensive programs designed to integrate medical and social services (care coordination). The specific medical needs included in this review are:

- Preventive dental care
- Preventive medical care (based on general recommendations of the U.S. Preventive Services Task Force)
- Medical care related to the following ambulatory-care–sensitive conditions:
  ○ Urinary tract infections
  ○ Pressure ulcers
  ○ Diabetes and diabetic complications
  ○ Pneumonia
  ○ Asthma
  ○ Gastroenteritis
  ○ Hypertension
  ○ Obesity

Outcomes analyzed: This review focused on outcomes, patient experience, and care coordination process measures that could be used for evaluating quality improvement interventions that target or include people with disabilities. It viewed disability as a complicating condition and thus focused on generic outcomes measures for the general population or for broad classes of disability rather than on disability-specific outcomes.

Literature reviewed: Peer-reviewed English-language articles published between 1990 and March 2012 and indexed in the MEDLINE, PsychINFO, Education Resources Information Center (ERIC), and Center for International Rehabilitation Research Information & Exchange (CIRRIE) databases. The review was limited to research from the United States and from the United Kingdom, Canada, Australia/New Zealand, and the Netherlands, where service delivery settings were more likely to be applicable to the United States. The review identified 15 articles that addressed Key Question 1 and 45 that addressed Key Questions 2 and 3.

Analyses performed: Results were synthesized qualitatively. When possible, the International Classification of Functioning, Disability and Health was used as an organizing principle.4

### What Were the Key Findings?

Table A-7 summarizes the main results by Key Questions for this topic.

Table A-7 Disability Outcomes key findings

Key Question 1a: What general population outcomes have been validated on and/or adjusted to accommodate disabled populations?
The review found few examples of research that viewed disability as a complicating condition rather than as the main condition of focus. The 15 articles identified by the review that addressed this Key Question to some extent evaluated a total of 71 different outcomes measures for use in disability populations. Nearly half of these measures (48%) were evaluated by a single article that focused specifically on participation as an outcome among people with disabilities.5 An additional 28 measures (39%) were identified from a series of 5 papers focused on the state of outcomes measurement for rehabilitation. The remaining articles identified 5 general population outcomes that have been adapted for use in disability populations (Table 8 of full report), 2 outcomes measures developed for 1 disability group that have been expanded for use in a different disability group (Table 9 of full report), and four newly developed measures (Table 10 of full report).6 Table 4 of the full report lists all 71 outcomes measures and their source article. The review also identified a rehabilitation outcomes database (www.rehabmeasures.org) that contains measures specifically for use in patients with stroke or spinal cord injuries and is currently being updated with measures for patients with traumatic brain injury. Another consensus-based measure development effort noted by the review authors is developing core measure sets aimed at specific chronic medical conditions for use in patients with disabilities.7 Thus far, this effort has developed core measure sets for 14 conditions, ranging from breast cancer and depression to obesity and rheumatoid arthritis. The review also identified a compendium of 28 rehabilitation outcomes measures, culled from among 300 initially reviewed, for use in community settings. The set of measures may be found in Table 7 of the full report.
Key Question 1b: What types of modifiers or case-mix adjusters have been used with the general population outcomes to recognize the special circumstances of people with disabilities?
The review did not identify any studies that addressed this Key Question using a mixed-study sample that included both disabled and nondisabled participants.
Key Question 1c: What are key parameters for measuring processes related to basic service care access for people with disabilities?
The review also did not identify any studies that addressed this Key Question. The authors caution that the decision to limit the scope of this review to an illustrative set of medical conditions may have prevented them from identifying relevant literature that addresses other particular conditions.
Key Questions 2 and 3: What measures have been used to assess effectiveness of care for people with disabilities living in the community in the context of coordination among health providers and between community organizations and health providers?
The review identified 44 studies (from 45 articles) that addressed these research questions. The review authors synthesized evidence for these Key Questions together because most studies (77%) evaluated interventions that included both coordination among health care providers (Key Question 2) and coordination between health care providers and social support (Key Question 3). More than 100 different measures were used to evaluate care coordination interventions. Health and level of functioning, and costs or utilization were the most commonly used types of outcomes measures, but patient or caregiver experience of care was also commonly measured. The specific instruments used to measure these general types of outcomes varied widely. Some measures were developed for use in general populations, such as the Short Form (SF)-36 and SF-8 (measures of health and functioning), Patient Assessment of Care for Chronic Conditions (PACIC), Consumer Assessment of Healthcare Providers and Systems (CAHPS) (measures of experience of care), and the rate of emergency room visits or hospitalization (measures of utilization). Others were more specific to people with disabilities, such as measures of activities of daily living or instrumental activities of daily living dependencies, survival without institutionalization (measures of functioning), and rate or frequency of nursing home stays or use of adult daycare centers (measures of utilization). The review also identified the National Core Indicators collaborative as an important potential source of outcomes measures for people with disabilities. The initiative aims to develop a standard set of performance measures for use in evaluating the quality of developmental disability services. The complete set may be found in Table 14 of the full report.

## 8 Interventions To Improve Health Care and Palliative Care for Advanced and Serious Illness

### What Is Palliative Care?

Palliative care is medical care focused on improving the quality of life of people facing serious or life-threatening illness, including end of life. It is often provided as a service or quality improvement intervention; emphasizes pain and symptom management, communication, and coordination; and can be delivered in any setting. This review also included end-of-life care and hospice, both subsets of palliative care:

- End-of-life care is care that is delivered to dying patients.
- Hospice is a care delivery system and insurance benefit for patients in the last months of life who have chosen quality of life as the primary goal of care. It is delivered wherever the patient resides; in the United States, this includes the home, special inpatient units, and nursing homes.

### What Is an Advanced or Serious Illness?

The review authors defined the population of interest as seriously ill patients and those with advanced disease (such as people living with advanced cancer or intensive care unit patients at high risk of dying) who are unlikely to be cured, recover, or be stabilized.

### What Is the Quality Gap Addressed by This Topic?

Evidence abounds that there is room for much improvement in the quality of palliative care for patients with advanced and serious illness. Pain remains undertreated for many patients. Despite effective therapies and clinical practice guidelines to facilitate pain management,19,20 patients with terminal cancer frequently are not offered alternatives to chemotherapy, are not educated about the uncertain benefits of such treatment, or are unaware of their prognosis,21 and in 2009, fewer than half of patients who died in the United States received any hospice care.22 Furthermore, a previous systematic review of hospice care reported that family members experienced unmet needs for family support (18.2 percent) and emotional support (9.8 percent).23 These gaps highlight the need for quality improvement interventions that improve outcomes for patients with advanced and serious illness and their caregivers. The review authors specifically targeted evidence regarding palliative care in hospice, where a previous systematic review identified quality gaps,23 and in nursing homes, where prior systematic reviews related to end-of-life care are lacking.

### Who Is Interested in the Topic?

This review aimed to evaluate the effectiveness of palliative care quality improvement interventions for patients with advanced and serious illness. The results of the review will be of interest to organizations investing in palliative care quality improvement programs and to directors of and participants in such initiatives. Furthermore, it is likely to be of interest to providers working in palliative care and hospice programs or in settings with significant numbers of patients with advanced and serious illness (e.g., cancer centers, medicine inpatient units, nursing homes). Researchers and research funders with an interest in palliative care or this population will find information about evidence gaps and weaknesses that may help guide future research agendas and study design. Patient advocacy groups will find information that may be leveraged to encourage use of best practices.

### What Evidence Are Stakeholders Seeking?

The Palliative Care review authors sought to answer the following Key Questions:

- Palliative Care Key Question 1: What is the effectiveness of health care and palliative care interventions for key targets and settings relevant to palliative care?
  ○ 1a: Specific targets: What is the effectiveness in terms of processes and outcomes for pain; communication and decisionmaking; continuity, coordination, and transitions of care; and patient and family distress in palliative care populations?
  ○ 1b: Specific settings: What is the effectiveness of interventions for any target of palliative care within hospice programs or nursing homes?
- Palliative Care Key Question 2: What is the evidence for different quality improvement models for improving palliative care?
  ○ 2a: What is the evidence for different types of quality improvement interventions?
  ○ 2b: What is the evidence for different models in palliative care: integrative (palliative care principles and interventions embedded into daily practice) compared with consultative (use of palliative care consults)?

For each intervention target area (e.g., pain; communication and decisionmaking; continuity, coordination, and transitions of care; patient and family distress), the reviewers analyzed either Key Question 2a or 2b, but not both, depending on which question was more applicable.

### What Is the Scope of the Review?

Population: Patients with advanced and serious illness. (See definition above.)

Outcomes analyzed: Patient and family satisfaction/perceptions of palliative care; patient symptoms, needs, distress, and quality of life; health care utilization, such as hospital admissions or do-not-resuscitate orders (but not costs); quality-of-care measures, such as timeliness of response to pain and other symptoms; family/caregiver psychosocial symptoms, support, needs, quality of life, and grief/bereavement.

Literature reviewed: The review authors searched for evidence between 2000 and 2011 from the following databases: PubMed, CINAHL, PsycINFO, Cochrane, and DARE. The final review included 96 articles describing 90 studies. Twelve studies that addressed targets of continuity, coordination of care, and/or transitions in care were randomized controlled trials.

Analyses performed: Due to heterogeneity of interventions, outcomes, and outcome reporting, the data could not be synthesized and a meta-analysis was not conducted. Instead, the information was described in a systematic manner. The review authors categorized included studies by target and setting of the intervention, including a category for interventions that focused on multiple targets or targets other than the primary ones.

### What Were the Key Findings?

Table A-8 summarizes the main results by Key Questions for this topic.

Table A-8 Palliative Care key findings

Key Question 1a: In palliative care populations, what is the effectiveness of health care and palliative care interventions that target pain; communication and decisionmaking; continuity, coordination, and transitions of care; and patient and family distress?
Among palliative care populations, the review found evidence that interventions that targeted pain improved pain (moderate strength of evidence) but not quality of life (low strength of evidence). Nineteen of the 21 studies of pain focused on patients with cancer. Interventions that targeted communication and decisionmaking improved health care utilization (moderate strength of evidence), but not patient satisfaction (low strength of evidence) or family satisfaction (insufficient strength of evidence). Interventions that targeted continuity, coordination, and transitions of care improved patient and caregiver satisfaction (moderate strength of evidence) but not quality of life, overall symptoms, or health care utilization (low strength of evidence). There was only low strength of evidence that interventions targeting patient distress were effective, with 2 of 7 randomized controlled trials (RCTs) showing significant improvement.
Key Question 1b: What is the effectiveness of interventions for any target of palliative care within hospice programs or nursing homes?
Only a handful of studies for either setting were found for each intervention target, limiting the ability to draw conclusions. Altogether, only 2 studies were identified in the hospice setting and 9 in the nursing home setting. Of these 9 nursing home studies, 7 showed improvements in at least 1 outcome following palliative care interventions such as care pathways, pain assessment, and education. In 2 RCTs that focused on pain screening interventions among patients with end-stage dementia in nursing homes, both reported statistically significant improvement in pain-related outcomes (i.e., pain assessment and adherence to pain medication) with the intervention. One RCT that investigated an intervention to educate patients, providers, and families about advance directives found a statistically significant decrease in average hospital days among the intervention group (2.61 days vs. 5.86 days, p = 0.01).24
Key Question 2a: What is the evidence for different types of quality improvement interventions improving palliative care?
Six of 9 studies using patient-centered quality improvement interventions (patient/family/caregiver education and promotion of self-management) to target continuity, coordination of care, and transitions showed a significant improvement in patient satisfaction and quality of life. In contrast, none of 6 studies that used only provider-centered quality improvement interventions (i.e., provider reminder systems, facilitated relay of clinical data to providers, or provider education) without patient-centered interventions to target this area demonstrated improved quality of life or satisfaction. A majority of interventions targeting pain were patient centered (18 of 21), while only 14 percent were exclusively provider focused. Combining print and video material in patient-centered pain interventions seemed most effective; 4 of 6 such studies showed improvements in pain, while only 1 of 3 studies using only 1 modality (print or video but not both) showed improvement.
Key Question 2b: What is the evidence for different models in palliative care (integrative vs. consultative) improving palliative care?
This question was analyzed only for interventions targeting communication and decisionmaking. The review found some evidence supporting the effectiveness of both integrative care models (with 4 of 8 studies showing improvement) and consultative care models (with 6 of 8 studies showing improvement) for this target area.

## References

1 Iezzoni L. Developing Quality of Care Measures for People with Disabilities: Summary of Expert Meeting. AHRQ Publication No. 10-0103. Rockville, MD. Agency for Healthcare Research and Quality. 2010. www.ahrq.gov/populations/devqmdis. January 2010.
2 Committee on Identifying Priority Areas for Quality Improvement. Priority Areas for National Action: Transforming Health Care Quality. Washington, DC. The National Academies Press. 2003.
3 Sofaer S, Kreling B, Carmel M. Coordination of Care for Persons With Disabilities Enrolled in Medicaid Managed Care. A Conceptual Framework To Guide the Development of Measures. Baruch College School of Public Affairs: Office of Disability, Aging, and Long-Term Care Policy Office of the Assistant Secretary for Planning and Evaluation. U.S. Department of Health and Human Services. 2000.
4 World Health Organization. International Classification of Functioning, Disability and Health: ICF. Geneva, Switzerland. World Health Organization. 2001.
5 Resnik L, Plow MA. Measuring participation as defined by the international classification of functioning, disability and health: an evaluation of existing measures. Arch Phys Med Rehabil. May. 2009;90(5):856-66. [pmid: 19406308].
6 Butler M, Kane RL, Larson S, et al. Quality Improvement Measurement of Outcomes for People With Disabilities. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Pubication No. 12(13)-E013-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
7 Cieza A, Ewert T, Ustun TB, et al. Development of ICF Core Sets for patients with chronic conditions. J Rehabil Med. Jul. 2004;(44 Suppl):9-11. [pmid: 15370742].
8 Committee on Quality Health Care in America, Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC. The National Academies Press. 2001.
9 Shojania KG, McDonald KM, Wachter RM, et al. Series Overview and Methodology. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04-0051-1. Rockville, MD. Agency for Healthcare Research and Quality. 2004;1. www.ncbi.nlm.nih.gov/books/NBK43908/.
10 Health 2.0. San Francisco, CA. 2011. http://healthblawg.sharedby.co/8d9f35b3d72281e8/?web=d7c1b8&dst=http%3A//www.health2con.com/conferences/san-francisco-2011/. March 1, 2012.
11 Fung CH, Lim YW, Mattke S, et al. Systematic review: the evidence that publishing patient care performance data improves quality of care. Ann Intern Med. Jan. 15. 2008;148(2):111-23. [pmid: 18195336].
12 Marshall MN, Shekelle PG, Leatherman S, et al. The public release of performance data: what do we expect to gain? A review of the evidence. JAMA. Apr. 12. 2000;283(14):1866-74. [pmid: 10770149].
13 Ketelaar Nicole ABM, Faber Marjan J, et al. Public Release of Performance Data in Changing the Behaviour of Healthcare Consumers, Professionals or Organisations, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
14 Smedley B, Stith A, Nelson A. Unequal Treatment: Confronting Racial and Ethnic Disparities in Health Care. Washington, DC. National Academies Press. 2003.
15 Frieden TR. Forward: CDC Health Disparities and Inequalities Report - United States, 2011. MMWR Surveill Summ. Jan. 14. 2011;60(Suppl):1-2. [pmid: 21430612].
16 Agency for Healthcare Research and Quality. National Healthcare Disparities Report, 2011. AHRQ Publication No. 12-0006. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.ahrq.gov/qual/qrdr11.htm.
17 Beach MC, Gary TL, Price EG, et al. Improving health care quality for racial/ethnic minorities: a systematic review of the best evidence regarding provider and organization interventions. BMC Public Health. 2006;6:104. [pmid: 16635262].
18 Coberley CR, Puckrein GA, Dobbs AC, et al. Effectiveness of disease management programs on improving diabetes care for individuals in health-disparate areas. Dis Manag. Jun. 2007;10(3):147-55. [pmid: 17590145].
19 Johnson VM, Teno JM, Bourbonniere M, et al. Palliative care needs of cancer patients in U.S. nursing homes. J Palliative Med. Apr. 2005;8(2):273-9. [pmid: 15890038].
20 Deandrea S, Montanari M, Moja L, et al. Prevalence of undertreatment in cancer pain. A review of published literature. Ann Oncol. 2008;19(12):1985-91. [pmid: 18632721].
21 Gattellari M, Voigt KJ, Butow PN, et al. When the treatment goal is not cure: are cancer patients equipped to make informed decisions?. J Clin Oncol. 2002;20(2):503-13. [pmid: 11786580].
22 Kirshen AJ, Roff SL. Defining palliative care competencies in Canadian geriatric medicine subspecialty training. J Am Geriatr Soc. 2011;59(10):1981-3. [pmid: 22091522].
23 National Hospice and Palliative Care Organization. NHPCO Facts and Figures: Hospice Care in America, 2010. Alexandria, VA. National Hospice and Palliative Care Organization. 2012. www.nhpco.org.
24 Molloy DW, Guyatt GH, Russo R, et al. Systematic implementation of an advance directive program in nursing homes: a randomized controlled trial. JAMA. Mar. 15. 2000;283(11):1437-44. [pmid: 10732933].
25 Agency for Healthcare Research and Quality. Patient Centered Medical Home Resource Center. 2011. http://pcmh.ahrq.gov/. January 24, 2011.
26 Durlak JA. How to select, calculate, and interpret effect sizes. J Pediatr Psychol. Oct. 2009;34(9):917-28. [pmid: 19223279].
27 Williams JW, Jackson GL, Powers BJ, et al. The Patient-Centered Medical Home. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 12-E008-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
28 Horan TC, Andrus M, Dudeck MA. CDC/NHSN surveillance definition of health care-associated infection and criteria for specific types of infections in the acute care setting. Am J Infect Control. Jun. 2008;36(5):309-32. [pmid: 18538699].
29 Klevens RM, Edwards JR, Richards CL Jr, et al. Estimating health care-associated infections and deaths in U.S. hospitals, 2002. Public Health Rep. Mar-Apr. 2007;122(2):160-6. [pmid: 17357358].
30 Cardo D, Dennehy PH, Halverson P, et al. Moving toward elimination of healthcare-associated infections: a call to action. Am J Infect Control. Nov. 2010;38(9):671-5. [pmid: 21058460].
31 Ranji SR, Shetty K, Posley KA, et al. Prevention of Healthcare-Associated Infections. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04(07)-0051-6. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007;6. www.ncbi.nlm.nih.gov/pubmed/20734530.
32 Scott RD. The Direct Medical Costs of Healthcare-Associated Infections in U.S. Hospitals and the Benefits of Prevention. Publication No. CS200891-A. Atlanta, GA. Centers for Disease Control and Prevention. March. 2009.
33 Waters HR, Korn R Jr, Colantuoni E, et al. The business case for quality: economic analysis of the Michigan Keystone Patient Safety Program in ICUs. Am J Med Qual. Sep-Oct. 2011;26(5):333-9. [pmid: 21856956].
34 Berenholtz SM, Pronovost PJ, Lipsett PA, et al. Eliminating catheter-related bloodstream infections in the intensive care unit. Crit Care Med. Oct. 2004;32(10):2014-20. [pmid: 15483409].
35 Osterberg L, Blaschke T. Adherence to medication. N Engl J Med. Aug. 4. 2005;353(5):487-97. [pmid: 16079372].
36 Cramer JA, Roy A, Burrell A, et al. Medication compliance and persistence: terminology and definitions. Value Health. Jan-Feb. 2008;11(1):44-7. [pmid: 18237359].
37 Urquhart J, Vrijens B. New findings about patient adherence to prescribed drug dosing regimens: an introduction to pharmionics. Eur J Hosp Pharm Sci. 2005;11(5):103-6.
38 Vrijens B, Vincze G, Kristanto P, et al. Adherence to prescribed antihypertensive drug treatments: longitudinal study of electronically compiled dosing histories. BMJ. May. 17. 2008;336(7653):1114-7. [pmid: 18480115].
39 Haynes RB, Ackloo E, Sahota N, et al. Interventions for enhancing medication adherence. Cochrane Database Syst Rev. 2008;(2):CD000011. [pmid: 18425859].
40 World Health Organization. Noncommunicable Diseases and Mental Health Cluster. Adherence to Long Term Therapies: Evidence for Action. Geneva, Switzerland. World Health Organization. 2003.
41 Peterson AM, Takiya L, Finley R. Meta-analysis of trials of interventions to improve medication adherence. Am J Health-Sys Pharm. Apr. 1. 2003;60(7):657-65. [pmid: 12701547].
42 Krueger KP, Berger BA, Felkey B. Medication adherence and persistence: a comprehensive review. Adv Ther. Jul-Aug. 2005;22(4):313-56. [pmid: 16418141].
43 Wagner EH. Chronic disease management: what will it take to improve care for chronic illness?. Effective Clin Pract. Aug-Sep. 1998;1(1):2-4. [pmid: 10345255].
44 Mauger Rothenberg B, Marbella A, Pines E, et al. Prevention of Healthcare-Associated Infections. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment No. 208. (Prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058.) AHRQ Publication No. 12(13)-E012-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.