# Results

## Included Studies

We included 157 systematic reviews reporting 308 meta-analyses (published between 1988 and 2003) for which complete data to reconstruct 2×2 tables of the individual studies were available. The meta-analyses contributing data to this empirical comparison represent approximately 59 percent of all test accuracy meta-analyses published during the study period and identified through our searches. We treated meta-analyses as independent observations even when they had common studies. The small amount of overlap does not introduce appreciable bias because overlap in studies is limited (between meta-analyses originating from the same systematic review) and uncommon (between systematic reviews).

The median number of studies in the included meta-analyses was 11 (25^th^–75^th^ percentile: 8–18). Included primary studies were generally small (median of the median number of affected individuals across meta-analyses = 30; median of the median number of unaffected individuals across meta-analyses = 62). Additional characteristics of the included meta-analyses and their component studies are presented in Table 2. The data summarized in the table highlight the diversity of sensitivity and specificity values encountered in our dataset.

Table 2 Descriptive characteristics of test accuracy meta-analyses

Characteristics | Median | 25^th^ Percentile | 75^th^ Percentile | Minimum | Maximum
Number of included primary studies | 11 | 8 | 18 | 6 | 61
Median number of affected individuals (cases)^*^ | 30 | 17 | 47 | 2 | 468
Median number of unaffected individuals (controls)^*^ | 61 | 29 | 106 | 8 | 9979
Median ratio of affected (cases) to unaffected (control) individuals | 0.46 | 0.21 | 1.04 | 0.002 | 15.14
Median number of “positive” test results | 32 | 19 | 61 | 3 | 549
Median number of “negative” test results | 59 | 30 | 99 | 7 | 9415
Median ratio of “positive” to “negative” test results | 0.51 | 0.30 | 1 | 0.01 | 7.17
Median true positive count | 21 | 12 | 35 | 2 | 464
Median false positive count | 7 | 3 | 19 | 0 | 491
Median false negative count | 6 | 2 | 12 | 0 | 157
Median true negative count | 48 | 24 | 85 | 5 | 9,411
“Crude” † sensitivity | 0.77 | 0.58 | 0.88 | 0.15 | 0.99
“Crude”^†^ specificity | 0.86 | 0.77 | 0.93 | 0.18 | 1

* Based on the reference standard test used in each study.

† Calculated by summing the numerators and denominators of included studies (this is equivalent to a fixed effects meta-analysis using the exact binomial likelihood).

Some investigators have suggested that problems with convergence are a major concern when fitting the bivariate models for meta-analysis of test accuracy.23 In total, for 10 of 308 meta-analyses (3%) we could not obtain estimates from all methods listed in Table 1 and they have been excluded from the comparisons presented in the following sections.^g^

## Meta-Analysis of Sensitivity and Specificity

### Fixed Versus Random Effects Univariate Inverse Variance Meta-Analyses

Figure 1 compares the point estimates (logit-transformed) and confidence interval widths for univariate meta-analyses of sensitivity and specificity using fixed versus random effects inverse variance models. Overall, point estimates from the two methods are similar; however, the estimated uncertainty around each estimate is greater for random effect analyses because they incorporate between-study variability. We argue that meta-analysts are (almost) always interested in generalizable (to unobserved studies) summary estimates; in such cases random effects models are more appropriate, particularly in the presence of between-study heterogeneity (which is common in diagnostic test reviews). All subsequent comparisons in this report are limited to random effects models.

Figure 1 Comparison of point estimates and standard errors of summary sensitivity and specificity (logit scale; univariate DL random effects vs. fixed effect inverse variance)

Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate random and fixed effects meta-analyses of sensitivity and specificity. CI = confidence interval; DL = DerSimonian-Laird.

Figure 1 is a scatter plot presenting a comparison of point estimates and standard errors of summary logit-transformed sensitivity and specificity (univariate DerSimonian-Laird random effects vs. fixed effect inverse variance). Point estimates from the two methods are often similar; however, confidence interval widths are substantially larger with the DerSimonian-Laird method.

### Univariate Random Effects Meta-Analysis Methods

This section compares the results of alternative univariate meta-analysis methods for sensitivity and specificity.

#### Inverse Variance Versus ML Univariate Random Effects Meta-Analyses (Normal Approximation)

Figure 2 compares the point estimates (logit-transformed) and confidence interval widths for univariate meta-analyses of sensitivity and specificity using inverse variance versus ML random effects models based on the assumption of normal distributions for the logit-transformed probabilities. The point estimates from the two methods are very similar. However, the methods often produce different standard errors, resulting in different confidence interval widths. Figure 3 presents a histogram of the differences in estimated sensitivities and specificities (untransformed scale) between methods. The absolute differences are rarely greater than 2.5 percent.

Figure 2 Comparison of point estimates and standard errors of summary sensitivity and specificity (logit scale) from random effects meta-analyses using a normal approximation (estimation of heterogeneity with DL vs. MLE)

Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate random effects meta-analyses using the DerSimonian-Laird inverse variance method versus MLE. CI = confidence interval; DL = DerSimonian-Laird; MLE = maximum likelihood estimation.

Figure 2 is a scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate random effects meta-analyses using the DerSimonian-Laird inverse variance method vs. maximum likelihood estimation. The point estimates of the two methods are practically identical, however confidence interval widths are different. Generally, confidence interval widths are wider with maximum likleihood estimation, possibly because this method incorporates uncertainty in the estimation of the between study heterogeneity.

Figure 3 Histograms of differences in estimated summary sensitivity and specificity from univariate random effects meta-analyses (DerSimonian-Laird vs. MLE)

Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing univariate random effects meta-analyses using the DerSimonian-Laird inverse variance method versus MLE (both using a normal approximation for within-study variability). DL = DerSimonian-Laird; MLE = maximum likelihood estimation.

Figure 3 presents histograms of differences in estimated sensitivity and specificity from univariate random effects meta-analyses (DerSimonian-Laird vs. maximum likelihood estimation). The plots of sensitivity (left panel) and specificity (right panel) indicate that point estimates are fairly similar, with only a single case having a difference larger than 0.05 (a sinlge meta-analysis, and only for sensitivity).

#### Approximate Normal Versus Exact Binomial Univariate Random-Effects Meta-Analyses (MLE)

Figure 4 compares the point estimates (logit-transformed) and confidence interval widths from univariate random effect meta-analyses of sensitivity and specificity using a normal approximation versus the exact binomial likelihood (both models fit with MLE). The point estimates from the two models are often dissimilar, and differences are greater for sensitivity and specificity values that are closer to one. This may be explained in part by the need for continuity corrections when the normal approximation is used to model within-study variability. The need to add 0.5 (or any other constant) to each zero cell biases the estimated proportions towards lower values (towards 0.5). An additional reason may be that the estimates and variances are correlated;33 the variance is a function of the estimate and the sample size. Indeed, the variance is a function of the proportion in such a way that it gets larger as the proportion approaches the extremes (zero or one). Thus, proportion estimates near the extremes receive less weight in the meta-analysis compared to estimates near 0.5. The net effect is that summary sensitivity or specificity is biased towards 0.5. The aforementioned biases are not a problem for meta-analysis methods using the exact likelihood.

Figure 4 Comparison of point estimates and confidence interval widths of summary sensitivity and specificity (logit scale) from univariate random effects meta-analyses using the exact binomial likelihood versus using a normal approximation (both models fit using MLE)

Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate random effects meta-analyses using the exact binomial likelihood versus using an approximate normal likelihood to describe within-study variability CI = confidence interval width; MLE = maximum likelihood estimation.

Figure 4 presents a comparison of point estimates and confidence interval widths of summary sensitivity and specificity from univariate random effects meta-analyses using the exact binomial likelihood vs. using a normal approximation (both models fit using maximum likelihood estimation). The scatter plots idicate that point estimates using the exact binomial likelihood are generally larger compared to those using a normal approximation. A similar effect is observed for the confidence interval widths (the width is larger for estimation using the exact binomial likelihood). Please see the text for additional discussion of the reasons for these differences.

Further, in many cases the exact likelihood results in wider confidence intervals, indicating that the normal approximation leads to an underestimation of the uncertainty surrounding the summary estimates. (This phenomenon has been described in several simulation analyses that we summarize in our Discussion section). Figure 5 presents histograms of differences in estimated sensitivities and specificities (untransformed scale) between methods. It is not uncommon to have differences in summary sensitivity and specificity of 5 percent or higher. As mentioned, summary sensitivity and specificity obtained with the normal approximation tend to be smaller than those obtained from exact methods.

Figure 5 Histograms of differences in estimated summary sensitivity and specificity (univariate random effects meta-analyses using the exact binomial likelihood vs. a normal approximation; both models fit with MLE)

Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing univariate random effects meta-analyses using the exact binomial likelihood versus using a normal approximation for within-study variability (both models fit with MLE). MLE = maximum likelihood estimation.

Figure 5 presents histograms of differences in estimated sensitivity and specificity (univariate random effects meta-analyses using the exact binomial likelihood vs. a normal approximation; both models fit with maximum likelihood methods). The plots for sensitivity (left panel) and specificity (right panel) indicate that point estimates are generally larger when using the exact binomial likelihood. Several differences beyond 0.05 are observed both for sensitivity and specificity.

#### Factors That Influence the Difference Between Univariate Random Effects Meta-Analyses Using the Normal Versus Binomial Likelihood (both with MLE)

Figure 6 presents scatter plots of the differences (logit-transformed) of estimated sensitivity and specificity over factors that we hypothesized could affect results with various methods. Differences between methods were larger in meta-analyses where a large proportion of the available studies required a continuity correction (for the normal approximation) and in meta-analyses where studies were generally small. The total number of included studies in the meta-analysis generally had a smaller effect.

Figure 6 Differences of estimated sensitivity and specificity (logit scale, univariate random effects meta-analyses using the exact binomial likelihood vs. a normal approximation; both models fit with MLE) over meta-analysis characteristics

Note: Positive differences indicate that estimates from analyses using the binomial likelihood are larger than those from analyses using the normal approximation. Eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) to avoid distortion of the graph.

Figure 6 presents scatter plots of differences of estimated sensitivity and specificity (logit scale, univariate random effects meta-analyses using the exact binomial likelihood versus a normal approximation; both models fit with maximum likelihood estimation) over meta-analysis characteristics. Positive differences indicate that estimates from analyses using the binomial likelihood are larger than those from analyses using the normal approximation. Eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) to avoid distortion of the graph. Differences between methods are larger in meta-analyses where a large proportion of the available studies require a continuity correction (for the normal approximation) and in meta-analyses where studies are generally small. The total number of included studies in the meta-analysis generally has a smaller effect.

#### Summary for Univariate Meta-Analysis Methods

Figure 7 summarizes the comparisons of univariate analyses of sensitivity and specificity discussed in this report [fixed effect inverse variance (normal approximation); random effects using the DerSimonian-Laird method (normal approximation); random effects using MLE with a normal approximation; random effects using ML with the exact binomial likelihood)]. Fixed and random effects methods often produced different point estimates, reflecting the different weights assigned to each study by these methods. Among random effects methods, the greatest discrepancies were observed between methods using the exact binomial likelihood versus those relying on the normal approximation. This could be explained by the need for continuity corrections, or the fact that the logit-transformed proportions and their variance are correlated, both of which would result in a downward bias for the summary sensitivity and specificity.

Figure 7 Summary comparison of sensitivity and specificity estimates (logit scale) from all univariate methods considered in this report

Note: Estimates are logit-transformed.

Binomial = model using the exact binomial likelihood for within-study variability; DL -= DerSimonian-Laird; FE = fixed effect; IV = inverse variance; normal = model using a normal approximation for within-study variability; RE = random effects; MLE = maximum likelihood estimation.

Figure 7 presents a summary comparison of logit-transformed sensitivity and specificity estimates from all univariate methods considered in this report. The figure summarizes the information presented in Figures 1, 2, and 4.

### Bivariate Meta-Analysis Methods

This section compares the results of analyses based on alternative bivariate models for the joint meta-analysis of sensitivity and specificity.

#### Noniterative (Inverse Variance) Versus Iterative (MLE) Estimation of Between-Study Variability in Bivariate Random Effects Meta-Analyses (Normal Approximation)

Figure 8 compares the point estimates (logit-transformed) and confidence interval widths from bivariate random effects meta-analyses of sensitivity and specificity using a normal approximation to model within-study variability. We compare models that use a non-iterative estimator of between-study variance (a generalization of the DerSimonian-Laird method) versus an iterative estimator obtained with REML.25 Point estimates from the two methods were almost identical. However, MLE often (but not always) resulted in greater wider confidence intervals compared to the non-iterative method. This possibly reflects the inability of the non-iterative method to incorporate the uncertainty in the estimation of between-study heterogeneity. Figure 9 presents histograms of the differences in estimated sensitivities and specificities (untransformed scale) between the two methods. Differences in summary estimates higher than 2.5 percent are uncommon.

Figure 8 Comparison of point estimates and confidence interval widths of summary sensitivity and specificity (logit scale) from bivariate random effects methods using a normal approximation (multivariate DerSimonian-Laird inverse variance vs. MLE)

Note: Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from bivariate random effects meta-analyses using the multivariate DerSimonian-Laird and MLE methods (both with a normal approximation to represent within-study variability).

CI = confidence interval width; mult. DL = multivariate DerSimonian-Laird; MLE = maximum likelihood estimation.

Figure 8 compares the point estimates and confidence interval widths of summary sensitivity and specificity from bivariate random effects methods using a normal approximation (multivariate DerSimonian-Laird inverse variance vs. maximum likelihood estimation). The point estimates from the two methods are almost identical, however confidence interval widths are often different (generally larger with maximum likelihood).

Figure 9 Histograms of differences in estimated summary sensitivity and specificity from bivariate random effects meta-analyses with multivariate DerSimonian-Laird inverse variance versus MLE (both models using a normal approximation to represent within-study variability)

Note: Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing bivariate random effects meta-analysis using a normal approximation for 2 estimation methods: multivariate DerSimonian-Laird and MLE. Mult. DL = multivariate DerSimonian-Laird; MLE = maximum likelihood estimation.

Figure 9 presents histograms of absolute differences in estimated sensitivity and specificity from bivariate random effects meta-analyses with multivariate DerSimonian-Laird inverse variance vs. maximum likelihood estimation (both models using a normal approximation to represent within-study variability). The plots indicate that point estimates are fairly similar with no differences being greater than 0.05.

#### Approximate Normal Versus Exact Binomial Bivariate Random-Effects Meta-Analyses (MLE)

Figure 10 compares the point estimates (logit-transformed) and confidence interval widths for bivariate random effects meta-analyses of sensitivity and specificity using the exact binomial likelihood versus using a normal approximation for within-study variability. It is evident that point estimates from the two methods are often dissimilar, and that differences are greater toward high sensitivity and specificity values (when they approach 1); this most likely follows from the need for continuity corrections when the normal approximation is used, which will tend to bias the estimated proportion toward 0.5. Further, in many cases the exact likelihood results in wider confidence intervals. Figure 11 presents histograms of the differences in estimated sensitivities and specificities (untransformed scale) between methods. The results indicate that differences higher than 5% are not uncommon and typically suggest underestimation of sensitivity and specificity in meta-analyses using a normal approximation (compared to those using the exact binomial likelihood).

Figure 10 Comparison of point estimates and confidence interval widths of summary sensitivity and specificity (logit scale) from bivariate random effects meta-analyses (approximate normal vs. exact binomial; both models fit with MLE)

Note: Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from bivariate random effects meta-analyses using the exact binomial likelihood versus using an approximate normal likelihood to describe within-study variability.

CI = confidence interval; MLE = maximum likelihood estimation.

Figure 10 presents comparisons of point estimates and confidence interval widths of summary sensitivity and specificity from bivariate random effects meta-analyses (approximate normal vs. exact binomial; both models fit with maximum likelihood estimation). The scatter plots demonstrate that point estimates and confidence interval widths are substantially different between the two methods (both tend to be larger with the exact binomial likelihood). Please see the main text for additional discussion of these differences.

Figure 11 Histograms of differences in estimated summary sensitivity and specificity from bivariate random effects meta-analyses (approximate normal vs. exact binomial; both models fit with MLE)

Note: Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing bivariate random effects meta-analysis using the exact binomial likelihood versus using a normal approximation for within-study variability.

MLE = maximum likelihood estimation.

Figure 11 presents histograms of absolute differences in estimated sensitivity and specificity from bivariate random effects meta-analyses (approximate normal vs. exact binomial; both models fit with maximum likelihood estimation). The plots for sensitivity (left panel) and specificity (right panel) demonstrate that point estimates using the exact binomial likelihood are substantially larger compared to those from the normal approximation. In several cases the difference is greater than 0.05.

#### Factors Influencing the Difference Between Bivariate Random Effects Meta-Analyses Using the Normal Versus Binomial Likelihood (Both With MLE)

Figure 12 presents scatter plots of the differences (logit-transformed) of estimated sensitivity and specificity versus factors that we hypothesized could affect estimation. The results demonstrate that differences between methods were larger in meta-analyses in which a large proportion of the available studies required a continuity correction (for the normal approximation) and in meta-analyses where studies were generally small. The total number of included studies in the meta-analysis generally had a smaller effect.

Figure 12 Differences of estimated sensitivity and specificity (logit scale, bivariate random effects meta-analyses using the exact binomial likelihood vs. a normal approximation; both models fit with MLE) over meta-analysis characteristics

Note: Positive differences indicate that estimates using the binomial likelihood are larger than those using the normal approximation. Eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) to avoid distortion of the graph.

Figure 12 presents scatter plots of differences of estimated sensitivity and specificity (logit scale, bivariate random effects meta-analyses using the exact binomial likelihood versus a normal approximation; both models fit with maximum likelihood estimation) over meta-analysis characteristics. Positive differences indicate that estimates using the binomial likelihood are larger than those using the normal approximation. Eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) to avoid distortion of the graph. The results demonstrate that differences between methods are larger in meta-analyses in which a large proportion of the available studies require a continuity correction (for the normal approximation) and in meta-analyses where studies are generally small. The total number of included studies in the meta-analysis generally has a smaller effect.

#### Bayesian Methods Versus MLE for the Binomial Bivariate Random Effects Model (Exact Likelihood)

Figure 13 compares the point estimates (logit-transformed) and confidence or credibility interval widths for bivariate random effects meta-analyses of sensitivity and specificity using fully Bayesian methods and MLE (both based on the exact binomial likelihood for within-study variability). Point estimates from the two methods were almost identical. However, the Bayesian model typically resulted in substantially larger credibility interval widths, indicating greater uncertainty around the sensitivity and specificity estimates compared to MLE. Figure 14 presents histograms of the differences in estimated sensitivities and specificities (untransformed scale) between the two methods, confirming that point estimate differences higher than 5 percent were very uncommon.

Figure 13 Comparison of point estimates and confidence/credibility interval widths of summary sensitivity and specificity (logit scale) from bivariate random effects meta-analyses (Bayesian versus MLE; both models using the exact binomial likelihood to represent within-study variability)

Note: Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from bivariate random effects models using fully Bayesian versus MLE estimation (both using the exact binomial likelihood to represent within-study variability)

CI = confidence interval; CrI = credibility interval; MLE = maximum likelihood estimation.

Figure 13 presents comparisons of point estimates and confidence/credibility interval widths of summary sensitivity and specificity from bivariate random effects meta-analyses (Bayesian vs. maximum likelihood estimation; both models using the exact binomial likelihood to represent within-study variability). The scatter plots demonstrate that the point estimates for sensitivity and specificity are fairly similar with the two methods. However, confidence interval widths are substantially different (generally larger in the Bayesian analyses). Please see the main text for additional discussion of these differences.

Figure 14 Histograms of differences in estimated summary sensitivity and specificity from bivariate random effects meta-analyses fit using fully Bayesian versus MLE estimation (using the exact binomial likelihood to represent within-study variability)

Note: Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing bivariate random effects meta-analysis models fit using fully Bayesian versus MLE (both models used the exact binomial likelihood to represent within-study variability)

MLE = maximum likelihood estimation.

Figure 14 presents histograms of absolute differences in estimated sensitivity and specificity from bivariate random effects meta-analyses fit using fully Bayesian vs. maximum likelihood estimation (using the exact binomial likelihood to represent within-study variability). The plots for sensitivity (left panel) and specificity (right panel) indicate that large differences in the point estimates are rare. The absolute difference was larger than 0.05 in only a single meta-analysis (and only for sensitivity).

#### Factors Influencing the Difference Between Bivariate Random Effects Meta-Analyses Using the Binomial Likelihood (MLE vs. Bayesian)

Figure 15 presents scatter plots of the differences (logit-transformed) of estimated sensitivity and specificity over factors that we hypothesized could affect estimation. Generally differences between methods were small. However, differences were smaller with increasing number of included studies and increasing median number of participants per study. Differences were larger with increasing proportion of studies requiring a continuity correction, possibly reflecting the larger impact of the priors in such cases.

Figure 15 Differences of estimated logit sensitivity and specificity between models fit with Bayesian methods versus MLE (both from bivariate random effects meta-analyses using the exact binomial likelihood) over meta-analysis characteristics

Note: Positive differences indicate that estimates from Bayesian analyses are larger than those from MLE. Three datapoints (1 for sensitivity and 2 for specificity) with absolute differences between methods larger than 1 have not been plotted to avoid distortion in the graph. An additional eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) for the same reason.

Figure 15 presents scatter plots of differences of estimated logit sensitivity and specificity between models fit with Bayesian methods versus maximum likelihood estimation (both from bivariate random effects meta-analyses using the exact binomial likelihood) over meta-analysis characteristics. Positive differences indicate that estimates from Bayesian analyses are larger than those from maximum likelihood estimation. Three datapoints (1 for sensitivity and 2 for specificity) with absolute differences between methods larger than 1 have not been plotted to avoid distortion in the graph. An additional eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) for the same reason. Generally differences between methods are small. However, differences are smaller with increasing number of included studies and increasing median number of participants per study. Differences are larger with increasing proportion of studies requiring a continuity correction, possibly reflecting the larger impact of the priors in such cases.

#### Summary for Bivariate Meta-Analysis Methods

Figure 16 summarizes the comparisons of bivariate analyses of sensitivity and specificity discussed in this report (random effects using a generalization of the DerSimonian-Laird method [normal approximation]; random effects using REML [normal approximation]; random effects using ML [exact binomial likelihood]; and Bayesian random effects using the exact binomial likelihood). The greatest discrepancies in meta-analytic point estimates were observed between methods using the exact binomial likelihood versus those relying on the normal approximation. This could be explained by the need for continuity corrections, or the fact that the logit-transformed proportions and their variance are correlated, both of which would result in a downward bias for the summary sensitivity and specificity.

Figure 16 Summary comparison of sensitivity and specificity estimates (logit scale) from all univariate methods considered in this report

Binomial = model using the exact binomial likelihood for within-study variability; mult. DL= multivariate DerSimonian-Laird; normal = model using a normal approximation for within-study variability; MLE = maximum likelihood estimation.

Figure 16 presents a summary comparison of logit-transformed sensitivity and specificity estimates from all univariate methods considered in this report. The figure summarizes the results presented in Figures 7, 9, and 11.

#### Estimation of the Between-Study Correlation (Inverse Variance, MLE, and Bayesian Bivariate Models)

The bivariate models, both using a normal approximation and the exact binomial likelihood, allow estimation of the correlation of sensitivity and specificity at the between-study level. Figure 17 presents scatter plots of the estimated correlation from four bivariate models: the two models with a normal approximation (fit using either the multivariate DerSimonian-Laird method or REML), and two models using the exact binomial likelihood to describe within-study variability (fit using ML or a fully Bayesian approach). It is obvious that these methods produce different distributions of correlations, with the maximum likelihood approaches often returning estimated correlations equal to -1 (and less frequently, 1). In contrast the Bayesian model rarely produces such extreme correlation values. Negative values are more common with all approaches, but the estimated correlations from all methods are sometimes positive (Table 3). Negative correlation values are consistent with the existence of threshold effects (i.e., the trade-off between sensitivity and specificity) in meta-analyses of test accuracy. The differences in the correlation estimates are highlighted by Figure 18, which is a matrix scatter plot of the results from the same 4 methods. Figure 19 presents histograms of the differences in correlation estimates between alternative methods.

Figure 17 Histograms of the estimated correlation between sensitivity and specificity from the three bivariate methods compared in this report

Note: Histograms of the estimated correlation between sensitivity and specificity from bivariate random effects meta-analysis models using: (top left) normal approximation with multivariate DerSimonian-Laird method; (top right) normal approximation with MLE; (bottom left) exact binomial likelihood with MLE; (bottom right) exact binomial likelihood with Bayesian model. Mult. DL = multivariate DerSimonian-Laird; MLE = maximum likelihood estimation.

Figure 17 presents histograms of the estimated correlation between sensitivity and specificity from the three bivariate methods compared in this report. The graph consists of 4 histograms of the estimated correlation between sensitivity and specificity from bivariate random effects meta-analysis models using: (top left) normal approximation with multivariate DerSimonian-Laird (multivariate DL); (top right) normal approximation with maximum likelihood estimation; (bottom left) exact binomial likelihood with maximum likelihood estimation; (bottom right) exact binomial likelihood with Bayesian model. All non-Bayesian methods produce extreme values (-1 or 1) in a substantial proportion of meta-analyses (this is particularly true for methods using the normal approximation). In contrast, Bayesian methods never produce such extreme values. Negative estimated values are more common than positive values for all 4 methods. Please see the main text for additional discussion of the differences between these methods.

Table 3 Estimated correlation by different bivariate methods

Method (Model/Approach for Within-Study Variability/Model Fitting Method) | Estimated Correlation <0 N (%)
BREMA, normal, mult. DL^*^ | 208 (70)
BREMA, normal, MLE | 214 (72)
BREMA, binomial, MLE | 203 (68)
BREMA, binomial, Bayesian | 200 (67)

* In one meta-analysis the correlation could not be estimated.

BREMA = bivariate random effects meta-analysis; mult. DL = multivariate DerSimonian-Laird; MLE = maximum likelihood estimation.

Figure 18 Matrix scatter plot of correlation estimates from the four bivariate methods considered in this report

Binomial = model using the exact binomial likelihood to describe within-study variability; mult. DL = multivariate DerSimonian-Laird; normal = model using an approximate normal likelihood to describe within-study variability; MLE = maximum likelihood estimation.

Figure 18 is a matrix scatter plot of correlation estimates from the 4 bivariate methods considered in this report. The figure demonstrates that agreement is moderate between the bivariate methods using the binomial likelihood (maximum likelihood and Bayesian methods). All other pairwise comparisons indicate that different methods often produce substantially different results.

Figure 19 Histograms of differences in correlation estimates from bivariate random effects meta-analyses (multivariate DerSimonian-Laird model using a normal approximation; MLE using a normal approximation; MLE using the exact binomial likelihood; and fully Bayesian model using the exact binomial likelihood)

Note: Histograms of differences in correlation estimates between models: top panel, multivariate DerSimonian-Laird method (with a normal approximation) versus MLE (with a normal approximation); middle panel, MLE with the exact binomial likelihood versus MLE with a normal approximation; bottom panel, Bayesian model (exact binomial likelihood) versus MLE (exact binomial likelihood).

ρ = correlation; bin. = model using the exact binomial likelihood; MLE = maximum likelihood estimation; norm. = model using a normal approximation.

Figure 19 summarizes the absolute differences of correlation estimates from bivariate random effects meta-analyses (multivariate DerSimonian-Laird model using a normal approximation; maximum likelihood estimation using a normal approximation; maximum likelihood estimation using the exact binomial likelihood; and fully Bayesian model using the exact binomial likelihood). The difference plots compare correlation estimates between pairs of meta-analysis models: top panel, multivariate DerSimonian-Laird method (with a normal approximation) vs. maximum likelihood (with a normal approximation); middle panel, maximum likelihood (with the exact binomial likelihood) vs. maximum likelihood (with a normal approximation); bottom panel, Bayesian model (exact binomial likelihood) vs. maximum likelihood estimation (exact binomial likelihood). Generally, larger differences are observed between the multivariate DerSimonian-Laird and maximum likelihood estimation with a normal approximation or between maximum likelihood analyses with different models for within study variability (exact binomial vs. approximate normal likelihood). Differences are smaller between Bayesian and maximum likelihood estimation methods (both using the exact binomial likelihood to model within study variability).

Generally, as is evident from the relatively wide confidence intervals, the correlation parameter is poorly estimated. As an example, Figure 20 shows the correlation point estimates and corresponding 95% confidence intervals from 228 studies for which they could be calculated (for studies where the correlation was estimated to be very close to -1 or +1, confidence intervals could not be calculated for numerical reasons). The confidence interval excluded negative correlation values in 5 of the 74 cases where the point estimate of the correlation was positive; in contrast, the confidence interval excluded positive correlation values in 43 of the 154 cases where the point estimate of the correlation was negative (Fisher exact p<0.001 for the difference in statistical significance).

Figure 20 Point estimates and 95% confidence intervals for the correlation of sensitivity and specificity, as estimated by the bivariate model using the exact binomial likelihood (MLE estimation)

Note: Estimates from the bivariate model using the exact binomial likelihood for within-study variability Point estimates are shown as red “x” symbols, extending lines represent 95% confidence intervals.

MLE = maximum likelihood estimation.

Figure 20 presents point estimates and 95% confidence intervals for the correlation between sensitivity and specificity, as estimated by the bivariate model using the exact binomial likelihood (maximum likelihood estimation) for the meta-analyses in which valid estimates could be obtained. Estimates were obtained from the bivariate model using the exact binomial likelihood to model within-study variability. In the graph, point estimates for the correlation are negative in approximately 2/3 of the studies. Correlation values larger than zero are rarely statistically significant. Confidence intervals are generally wide suggesting that the correlation is poorly estimated in many meta-analyses.

### Comparison of Univariate and Bivariate Methods

This section compares the results of univariate and bivariate methods for meta-analysis of sensitivity and specificity. We stratify comparisons by estimation method (non-iterative versus iterative estimation of heterogeneity) and by use of normal distribution versus the binomial likelihood to model within-study variation.

#### Univariate Versus Bivariate Random Effects Meta-Analyses Using the Normal Approximation and Noniterative Heterogeneity Estimators (DerSimonian-Laird and Multivariate DerSimonian-Laird Methods)

Figure 21 compares the point estimates (logit-transformed) and confidence interval widths for meta-analyses of sensitivity and specificity comparing univariate and bivariate random effects models (using a normal approximation for within-study variability). The univariate analyses used the DerSimonian-Laird method to estimate between-study heterogeneity; the bivariate analyses use a multivariate generalization of the same method. Overall, point estimates and confidence interval widths from the two methods were similar. Figure 22 presents histograms of the differences in estimated sensitivities and specificities (untransformed scale) between methods, which emphasizes the general concordance of the point estimates (no differences larger than 10% were observed and only occasional differences beyond 5%).

Figure 21 Comparison of point estimates and confidence interval widths of summary sensitivity and specificity (logit scale, univariate random effects vs. bivariate random effects inverse variance methods, both using a normal approximation for within-study variability and a noniterative estimator for heterogeneity)

Note: Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate random effects meta-analyses over bivariate random effects inverse variance (DerSimonian-Laird and multivariate DerSimonian-Laird) meta-analysis (with an approximate normal likelihood to describe within-study variability).

CI = confidence interval; DL = DerSimonian-Laird; mult. DL = multivariate DerSimonian-Laird.

Figure 21 presents comparisons of point estimates and confidence interval widths of summary logit-transformed sensitivity and specificity (univariate random effects vs. bivariate random effects inverse variance methods, both using a normal approximation for within-study variability). The scatter plots compare the estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate random effects meta-analyses over bivariate random effects inverse variance (DerSimonian-Laird and multivariate DerSimonian-Laird) meta-analysis (with an approximate normal likelihood to describe within-study variability). Point estimates and confidence intervals from the two methods are similar, both for sensitivity and specificity.

Figure 22 Histograms of differences in estimated summary sensitivity and specificity in univariate versus bivariate random effects inverse variance meta-analyses (both using a normal approximation for within-study variability)

Note: Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing bivariate versus univariate random effects inverse variance meta-analyses (Der-Simonian-Laird vs. multivariate DerSimonian-Laird; both using a normal approximation for within-study variability).

DL = DerSimonian-Laird; mult. DL = multivariate DerSimonian-Laird.

Figure 22 presents histograms of absolute differences in estimated sensitivity and specificity in univariate vs. bivariate random effects inverse variance meta-analyses (both using a normal approximation for within-study variability). The plots for sensitivity (left panel) and specificity (right panel) compare bivariate vs. univariate random effects inverse variance meta-analyses (Der-Simonian-Laird vs. multivariate DerSimonian-Laird; both using a normal approximation for within-study variability). Both graphs indicate that absolute differences are generally small (in a single meta-analysis the difference was beyond 0.05, and only for specificity).

#### Univariate Versus Bivariate Random Effects Meta-Analyses Using the Normal Approximation (Using MLE)

Figure 23 compares the point estimates (logit-transformed) and confidence interval widths for meta-analyses of sensitivity and specificity comparing univariate and bivariate random effects models using ML estimation (with a normal approximation for within-study variability). Overall, point estimates from the two methods are similar, however the uncertainty around the estimates is often different between methods; in many cases the bivariate model produces greater confidence interval widths, indicating larger uncertainty around estimates. Figure 24 presents histograms of the differences in estimated sensitivities and specificities (untransformed scale) between the two models; the graph emphasizes the general concordance of the point estimates of the two methods (only occasional differences beyond 2.5%).

Figure 23 Comparison of point estimates and standard errors of summary sensitivity and specificity (logit scale) from univariate versus bivariate random effects meta-analyses with MLE (using a normal approximation for within-study variability)

Note: Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate and bivariate random effects meta-analyses fit using MLE (with a normal approximation to represent within-study variability).

CI = confidence interval; MLE = maximum likelihood estimation.

Figure 23 presents comparisons of point estimates and standard errors of summary logit-transformed sensitivity and specificity from univariate vs. bivariate random effects meta-analyses with maximum likelihood estimation (using a normal approximation for within-study variability). The scatter plots of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate and bivariate random effects meta-analyses fit using maximum likelihood estimation (with an approximate normal likelihood to represent within-study variability) demonstrate that point estimates produced by the two methods are practically identical. The confidence interval width is often different between methods; however, no patern is evident.

Figure 24 Histograms of differences in estimated summary sensitivity and specificity (logit scale) from univariate and bivariate random effects meta-analyses with MLE (using a normal approximation to represent within-study variability for both models)

Note: Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing bivariate versus univariate random effects meta-analyses fit with MLE (using a normal approximation to represent within-study variability).

MLE = maximum likelihood estimation.

Figure 24 presents histograms of in estimated sensitivity and specificity between univariate and bivariate random effects meta-analyses with maximum likelihood estimation (using a normal approximation to represent within-study variability for both models). The plots for sensitivity (left panel) and specificity (right panel) comparing bivariate vs. univariate random effects meta-analyses fit with maximum likelihood methods (using a normal approximation to represent within-study variability) indicate that differences between point estimates are rarely big. In very few cases the absolute difference was close or above 0.05.

#### Univariate Versus Bivariate Random Effects Meta-Analyses Using the Exact Binomial Likelihood (MLE)

Figure 25 compares the point estimates (logit-transformed) and confidence interval widths for meta-analyses of sensitivity and specificity comparing univariate and bivariate models (using the exact binomial likelihood to represent within-study variability). Overall, point estimates and confidence interval widths from the two methods were similar. Figure 26 presents histograms of the differences in estimated sensitivities and specificities (untransformed scale) between methods and emphasizes the general concordance of the point estimates (only two discrepancies beyond 5%).

Figure 25 Comparison of point estimates and confidence interval widths of summary sensitivity and specificity (logit scale) from univariate versus bivariate random effects meta-analyses using the exact binomial likelihood (both models fit using MLE)

Note: Scatter plot of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate and bivariate random effect meta-analyses fit using MLE (both models using the exact binomial likelihood to represent within-study variability).

CI = confidence interval; MLE = maximum likelihood estimation.

Figure 25 presents comparisons of point estimates and confidence interval widths of summary logit-transformed sensitivity and specificity from univariate vs. bivariate random effects meta-analyses using the exact binomial likelihood (both models fit using maximum likelihood estimation). The scatter plots of estimated logit-transformed sensitivity, specificity and their corresponding confidence interval widths from univariate and bivariate random effect meta-analyses fit using maximum likelihood (both models using the exact binomial likelihood to represent within-study variability) indicate that diffrerences between methods are relatively small.

Figure 26 Histograms of differences in estimated summary sensitivity and specificity comparing univariate versus bivariate random effects meta-analyses fit with MLE (both models using the exact binomial likelihood to represent within-study variability)

Note: Histograms of differences in estimated summary sensitivity (left panel) and specificity (right panel) comparing bivariate versus univariate random effects models fit using MLE (both models used the exact binomial likelihood to represent within-study variability).

MLE = maximum likelihood estimation.

Figure 26 presents histograms of the absolute differences in estimated sensitivity and specificity comparing univariate vs. bivariate random effects meta-analyses fit with maximum likelihood (both models using the exact binomial likelihood to represent within-study variability). The plots for sensitivity (left panel) and specificity (right panel) comparing bivariate vs. univariate random effects models fit using maximum likelihood methods (both models used the exact binomial likelihood to represent within-study variability) demonstrate that differences are relatively small, with the absolute value being >0.05 in only 3 cases.

#### Factors Influencing the Difference Between Univariate and Bivariate Random Effects Meta-Analyses Using the Binomial Likelihood (MLE)

Figure 27 presents scatter plots of the differences (logit-transformed) of estimated sensitivity and specificity over factors that we hypothesized could affect estimation. The results demonstrate that differences between methods were generally small and that no meta-analysis characteristic had a large effect on the differences between methods.

Figure 27 Differences of estimated sensitivity and specificity (logit scale) comparing univariate versus bivariate random effects meta-analyses (both using the exact binomial likelihood and fit using MLE) over meta-analysis characteristics

Positive differences indicate that estimates from univariate meta-analysis are larger than those from bivariate meta-analysis. Four datapoints (2 for sensitivity and 2 for specificity) with absolute differences in estimated values between methods larger than 1 have not been plotted to avoid distortion of the graph. An additional eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) for the same reason.

Figure 27 presents scatter plots of differences of estimated sensitivity and specificity (logit scale) comparing univariate versus bivariate random effects meta-analyses (both using the exact binomial likelihood and fit using maximum likelihood estimation) over meta-analysis characteristics. Positive differences indicate that estimates from univariate meta-analysis are larger than those from bivariate meta-analysis. Four datapoints (2 for sensitivity and 2 for specificity) with absolute differences in estimated values between methods larger than 1 have not been plotted to avoid distortion of the graph. An additional eight meta-analyses with a median number of unaffected individuals >1000 have not been plotted (in the middle right panel) for the same reason. The results demonstrate that differences between methods are generally small and that no meta-analysis characteristic has a large effect on the differences between methods.

#### Summary for the Comparison of Univariate and Bivariate Methods

Figures 28 and 29 summarize the comparisons of effect sizes from all non-Bayesian random effects methods used in this report (univariate or bivariate; DerSimonian-Laird- or MLE-based; using the exact binomial likelihood or a normal approximation). Overall, the greatest discrepancies were observed between methods using the exact binomial likelihood versus those relying on the normal approximation. The point estimates from univariate and bivariate meta-analyses were similar both for methods using non-iterative (univariate or multivariate DerSimonian-Laird) or iterative (ML or REML) estimators of between-study variance.

Figure 28 Summary comparison of sensitivity estimates (logit scale) from all methods considered in this report

Binomial = model using the exact binomial likelihood; biv = bivariate; mult. DL = multivariate DerSimonian-Laird method; DL = DerSimonian-Laird model; normal = model using a normal approximation; MLE = maximum likelihood estimation; univ = univariate.

Figure 28 is a matrix scatter plot summarizing the comparisons of logit-transformed sensitivity estimates from all methods considered in this report. This Figure summarizes the findings presented in more detail in Figures 18, 20, and 22 regarding sensitivity.

Figure 29 Summary comparison of specificity estimates (logit scale) from all methods considered in this report

Binomial = model using the exact binomial likelihood; biv = bivariate; mult. DL = multivariate DerSimonian-Laird method; DL = DerSimonian-Laird model; normal = model using a normal approximation; MLE = maximum likelihood estimation; univ = univariate.

Figure 29 is a matrix scatter plot summarizing the comparisons of logit-transformed specificity estimates from all methods considered in this report. This figure summarizes the findings presented in more detail in Figures 18, 20, and 22 regarding specificity.

## Meta-Analysis in the Receiver Operating Characteristic Space

Methods for constructing ROC curves work by transforming a straight line that describes the bivariate distribution of logit-transformed sensitivity and specificity to the ROC space. The most common method used to obtain estimates of the intercept and slope of the straight line is the model proposed by Moses and Littenberg. Their approach is based on regressing the difference (D) of the logit-transformed sensitivity (η) and false positive rate (1-specificity = ξ) on their sum (S). Typically this method is implemented in a fixed effects framework (using both weighted and unweighted regression) and measurement error in S (the sum of logit-transformed sensitivity and specificity) is ignored. Hierarchical regression methods that overcome these limitations have been proposed but it is unclear whether they result in substantially different estimates of performance. The HSROC approach proposed by Rutter and Gatsonis is the method used in most published meta-analyses that employ such hierarchical models.

### Moses-Littenberg SROC Versus Rutter-Gatsonis HSROC

Figure 30 compares the slope in the logit space of ROC lines produced by the Moses-Littenberg (weighted and unweighted) and Rutter-Gatsonis methods. Figure 31 presents the SROC curves produced from these 3 methods for 24 randomly selected examples.

Figure 30 Scatter plot of the slopes of alternative SROC lines (logit space)

Note: Alternative SROC curves based on bivariate meta-analysis (to obtain estimates for the Rutter-Gatsonis HSROC; fit using maximum likelihood) or the Moses-Littenberg method Examples that resulted in extreme slope values (>10 or <-10) are not shown to avoid distortion of the graph.

SROC = summary receiver operating characteristic curve.

Figure 30 is a scatter plot of the slopes of alternative sROC lines (in the logit space). The graph presents slopes for sROC curves based on bivariate meta-analysis (fit using maximum likelihood) or the Moses-Littenberg method. Examples that resulted in extreme slope values (>10 or <-10) are not shown to avoid distortion of the graph. The graph demonstrates that in most cases the methods produce similar slope values. However, on some occasionsresults can be subsantially different.

Figure 31 SROC curves for 24 randomly selected meta-analyses (bivariate random effects model vs. Moses-Littenberg methods)

Note: Meta-analytic ROC curves for 24 randomly selected meta-analyses. The title for each panel contains the first author and year of publication for the corresponding review. Estimates for SROC curves were produced by bivariate meta-analysis (red lines; using the Rutter-Gatsonis formulation), and the unweighted (solid black line) and weighted (dashed black line) Moses-Littenberg methods.

HSROC = hierarchical summary receiver operating characteristic curve; SROC = receiver operating characteristic curve.

Figure 31 presents sROC curves for 24 randomly selected meta-analyses (bivariate random effects vs. Moses-Littenberg methods). The title for each panel contains the first author and year of publication for the corresponding review. HsROC curves were produced with the Rutter-Gatsonis HsROC method (red lines), and the unweighted (solid black line) and weighted (dashed black line) Moses-Littenberg methods. In the majority of cases the sROC curves from all three methods are very similar.

### Alternative SROC Curves Based on the Bivariate Model

The Rutter-Gatsonis HSROC curve is only one possible parameterization of the meta-analytic ROC curve. We followed Arends 2008^28^ to obtain alternative SROC curves based on the results of the bivariate random effects meta-analysis model using the exact binomial likelihood (fit with MLE). In Appendix C we present the regression lines corresponding to each alternative model. Importantly, the Rutter-Gatsonis HSROC curve always has a positive slope (because the slope is equal to the ratio of the square root of the variances of the logit-transformed sensitivity over the variance of the logit-transformed false positive rate). In contrast, the slopes of other HSROC curves are not always positive: the slopes estimated by MAR of η∼ξ, regression of η∼ξ, and of ξ∼η will be negative whenever the correlation between logit-sensitivity and logit-specificity is positive (i.e. when the covariance between logit-transformed true and false positive rates is negative); the slope of the regression line corresponding to the “D on S” model may also be negative in some cases, but this will depend on the relative values of the variances of logit-transformed sensitivity and specificity and their covariance.

Figure 32 presents the alternative SROC curves discussed above for 24 randomly selected meta-analyses: the Rutter-Gatsonis slopes are always positive, whereas in some examples the slopes from the D∼S, MAR of η ∼ ξ, η∼ξ, and ξ∼η models, are negative. The latter three models “track together” (i.e. either all have positive slopes or all have negative slopes). In contrast there are some examples where the D∼S model has a positive slope when the MAR, η∼ξ, and ξ∼η models have negative slopes.

Figure 32 HSROC curves for 24 randomly selected meta-analyses (alternative parameterizations of the HSROC curve)

Note: Alternative ROC curves based bivariate meta-analysis (fit using maximum likelihood) for 24 randomly selected meta-analyses The title for each panel contains the first author and year of publication for the corresponding review. Results are shown for the Rutter-Gatsonis (red lines), η∼ξ (green lines), ξ∼η (blue lines), D∼S (purple lines), and MAR of η∼ξ (black lines) parameterizations. See text and Appendix C for additional details.

D = logit(sensitivity) − logit(1 − specificity); S = logit(sensitivity) + logit(1 − specificity); MAR = major axis regression of η on ξ; η = logit(sensitivity); ξ = logit(1-specificity).

Figure 32 presents alternative parameterizations of the HsROC curve based on the bivariate meta-analysis model for 24 randomly selected meta-analyses. The title for each panel contains the first author and year of publication for the corresponding review. Results are shown for the Rutter-Gatsonis (red lines), η∼ξ (green lines), ξ∼η (blue lines), D∼S (purple lines), and MAR of η∼ξ (black lines) parameterizations. Here, D = logit(sensitivity) − logit(1 − specificity); S = logit(sensitivity) + logit(1 − specificity); MAR = major axis regression of η on ξ; η = logit(sensitivity); ξ = logit(1-specificity). In several cases the hsROC curves are substantially different between methods. Please see text and Appendix C for additional discussion of the differences between methods.

Figure 33 presents the study-level data and fitted HSROC curves for one of the datasets we analyzed34 (fourth dataset on the top row of Figure 32. This was a case where all regression methods (except the Rutter-Gatsonis model) resulted in a negative slope. The data points from the studies in this meta-analysis were clustered in the top left corner of the ROC space, many studies had sensitivities and specificities near 1, and the estimated correlation between sensitivity and specificity was positive. Note also that the differences between the fitted lines are less pronounced within the observed region of data.

Figure 33 Study results and fitted HSROC curves for an example dataset

Note: Alternative SROC curves for the meta-analysis by van Gelder, 2003^34^ (first dataset on the top row of Figure 32). Results are shown for the Rutter-Gatsonis (red lines), η∼ξ (green lines), ξ∼η (blue lines), D∼S (purple lines), and MAR of η∼ξ (black lines) parameterizations, in the ROC space (left panel) and the logit-transformed ROC space (right panel). All models were estimated using MLE. See text and Appendix C for additional details. For the logit space graph, in studies where the estimated false positive rate was 0 we used a value of 0.01 (because the logit of zero is undefined); this was done for illustration purposes only and does not affect the results of our analyses.

D = logit(sensitivity) − logit(1 − specificity); HSROC = hierarchical receiver operating characteristic; S = logit(sensitivity) + logit(1 − specificity); MAR = major axis regression of η on ξ; MLE = maximum likelihood estimation; η = logit(sensitivity); ξ = logit(1 − specificity).

Figure 33 presents the study-level results and fitted hsROC curves for an example dataset: the meta-analysis by vanGelder, 2003 (fourth dataset on the top row of Figure 28). Results are shown for the Rutter-Gatsonis (red lines), η∼ξ (green lines), ξ∼η (blue lines), D∼S (purple lines), and MAR of η∼ξ (black lines) parameterizations, in the ROC space (left panel) and the logit-transformed ROC space (right panel). Here, D = logit(sensitivity) − logit(1 − specificity); hsROC = hierarchical receiver operating characteristic; S = logit(sensitivity) + logit(1 − specificity); MAR = major axis regression of η on ξ; η = logit(sensitivity); ξ = logit(1 − specificity). All models were estimated using maximum likelihood methods. The data points from the studies in the meta-analysis were clustered in the top left corner of the ROC space, many studies had sensitivities and specificities near one, and the estimated correlation between sensitivity and specificity was positive. The differences between the fitted lines are most pronounced outside the observed region of data. Please see text and Appendix C for additional discussion of the differences between methods.

Table 4 shows that the regression of η∼ξ, regression of ξ∼η, and MAR of η ∼ ξ result in negative slopes in 32 percent of the meta-analyses we performed; the D∼S model results in negative slopes in 13 percent. By design, the Rutter-Gatsonis model always produces a positive slope. Figure 34 presents a matrix scatter plot of the slope values produced the different parameterizations of the HSROC curve, as well as those from the Moses-Litenberg method (weighted and unweighted).

Table 4 Slope of ROC line in the logit-space

Method | Meta-Analyses With Positive Slope N (%) | Meta-Analyses With Negative Slope N (%)
R & G | 298 (100) | 0 (0)
η ∼ ξ | 203 (68) | 95 (32)
ξ ∼ η | 203 (68) | 95 (32)
D ∼ S | 259 (87) | 39 (13)
MAR | 203 (68) | 95 (32)

D = logit(sensitivity) − logit(1 − specificity); S = logit(sensitivity) + logit(1 − specificity); MAR = major axis regression of logit(sensitivity) on logit(specificity); R & G = Rutter-Gatsonis model; η = logit-transformed sensitivity; ξ = logit-transformed specificity.

Figure 34 Scatter plot of the slopes of alternative SROC lines (logit space)

D = logit(sensitivity) − logit(1 − specificity); MAR = major axis regression; S = logit(sensitivity) + logit(1 − specificity); HSROC = hierarchical summary receiver operating characteristic curve; η = logit(sensitivity); ξ = logit(1 − specificity). Examples that resulted in extreme slope values (>10 or <-10) are not show to avoid distortion of the graph.

Figure 34 is a scatter plot of the slopes of alternative HsROC parameterizations based on the bivariate model (in the logit space). The figure demonstrates that in all examples the Rutter-Gatsonis method produces a positive slope for the hsROC line, whereas the slope sign is variable for other models. Please see the full text of the report and Appendix C for a detailed discussion of the behaviour of alternative hsROC curves derived from the bivariate meta-analysis model.

Appendix D presents a worked meta-analysis example applying all methods used in this report.