# References

1 Miettinen OS. The modern scientific physician: 4. The useful property of a diagnostic. CMAJ. 2001;165:910-911. [pmid: 11599332].
2 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. 2006;144:850-855. [pmid: 16754927].
3 Tatsioni A, Zarin DA, Aronson N, Samson DJ, Flamm CR, Schmid C, et al. Challenges in systematic reviews of diagnostic technologies. Ann Intern Med. 2005;142:1048-55. [pmid: 15968029].
4 Glas AS, Lijmer JG, Prins MH, Bonsel GJ, Bossuyt PM. The diagnostic odds ratio: a single indicator of test performance. J Clin Epidemiol. 2003;56:1129-35. [pmid: 14615004].
5 Gatsonis C, Paliwal P. Meta-analysis of diagnostic and screening test accuracy evaluations: methodologic primer. AJR Am J Roentgenol. 2006;187:271-81. [pmid: 16861527].
6 Lau J, Ioannidis JP, Schmid CH. Quantitative synthesis in systematic reviews. Ann Intern Med. 1997;127:820-826. [pmid: 9382404].
7 Lau J, Ioannidis JP, Schmid CH. Summing up evidence: one answer is not always enough. Lancet. 1998;351:123-27. [pmid: 9439507].
8 Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12:1293-316. [pmid: 8210827].
9 Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. 1993;13:313-21. [pmid: 8246704].
10 Reitsma JB, Glas AS, Rutjes AW, Scholten RJ, Bossuyt PM, Zwinderman AH. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58:982-90. [pmid: 16168343].
11 Dinnes J, Deeks J, Kirby J, Roderick P. A methodological review of how heterogeneity has been examined in systematic reviews of diagnostic test accuracy. Health Technol Assess. 2005;>9:1-113. iii.
12 Dahabreh IJ, Chung M, Kitsios GD, Terasawa T, Raman G, Tatsioni A, et al. Evaluating Practices and Developing Tools for Comparative Effectiveness Reviews of Diagnostic Test Accuracy. Task 1: Comprehensive Overview of Methods and Reporting of Meta- Analyses of Test Accuracy. AHRQ Methods Research Report. AHRQ Publication No 12-EHC044-EF. 2012.
13 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Stat Med. 2001;20:2865-84. [pmid: 11568945].
14 Harbord RM, Deeks JJ, Egger M, Whiting P, Sterne JA. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. 2007;8:239-51. [pmid: 16698768].
15 Van Houwelingen HC, Arends LR, Stijnen T. Advanced methods in meta-analysis: multivariate approach and meta-regression. Stat Med. 2002;21:589-624. [pmid: 11836738].
16 Harbord RM, Whiting P. metandi: Meta-analysis of diagnostic accuracy using hierarchical logistic regression. The Stata Journal. 2009;9:211-29.
17 Macaskill P. Empirical Bayes estimates generated in a hierarchical summary ROC analysis agreed closely with those of a full Bayesian analysis. J Clin Epidemiol. 2004;57:925-32. [pmid: 15504635].
18 Willis BH, Quigley M. Uptake of newer methodological developments and the deployment of meta-analysis in diagnostic test research: a systematic review. BMC Med Res Methodol. 2011;11:27. [pmid: 21401947].
19 Paul M, Riebler A, Bachmann LM, Rue H, Held L. Bayesian bivariate meta-analysis of diagnostic test studies using integrated nested Laplace approximations. Stat Med. 2010;29:1325-39. [pmid: 20101670].
20 Verde PE. Meta-analysis of diagnostic test data: a bivariate Bayesian modeling approach. Stat Med. 2010;29:3088-102. [pmid: 21170904].
21 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol. 2006;59:1331-32. [pmid: 17098577].
22 Harbord RM, Whiting P, Sterne JA, Egger M, Deeks JJ, Shang A, et al. An empirical comparison of methods for meta-analysis of diagnostic accuracy showed hierarchical models are necessary. J Clin Epidemiol. 2008;61:1095-103. [pmid: 19208372].
23 Simel DL, Bossuyt PM. Differences between univariate and bivariate models for summarizing diagnostic accuracy may not be large. J Clin Epidemiol. 2009;62:1292-300. [pmid: 19447007].
24 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
25 Jackson D, White IR, Thompson SG. Extending DerSimonian and Laird's methodology to perform multivariate random effects meta-analyses. Stat Med. 2010;29:1282-97. [pmid: 19408255].
26 Rabe-Hesketh S, Skrondal A. Multilevel and longitudinal modeling using Stata. Stata Corp. 2008.
27 Rabe-Hesketh S, Skrondal A, Pickles A. Reliable estimation of generalized linear mixed models using adaptive quadrature. The Stata Journal. 2002;2:1-21.
28 Arends LR, Hamza TH, van Houwelingen JC, Heijenbrok-Kal MH, Hunink MG, Stijnen T. Bivariate random effects meta-analysis of ROC curves. Med Decis Making. 2008;28:621-38. [pmid: 18591542].
29 Chappell FM, Raab GM, Wardlaw JM. When are summary ROC curves appropriate for diagnostic meta-analyses?. Stat Med. 2009;28:2653-68. [pmid: 19591118].
30 Scheffe H. A Method for Judging all Contrasts in the Analysis of Variance. Biometrika. 1953;40:87-104.
31 Cox NJ. Graphing agreement and disagreement. The Stata Journal. 2004;4:329-49.
32 Lunn DJ, Thomas A, Best N, Spiegelhalter D. WinBUGS -- a Bayesian modelling framework: concepts, structure, and extensibility. Statistics and Computing. 2011;10:325-37.
33 Chang BH, Waternaux C, Lipsitz S. Meta-analysis of binary data: which within study variance estimate to use?. Stat Med. 2001;20:1947-56. [pmid: 11427951].
34 Van Gelder JM. Computed tomographic angiography for detecting cerebral aneurysms: implications of aneurysm size distribution for the sensitivity, specificity, and likelihood ratios. Neurosurgery. 2003;53:597-605. [pmid: 12943576].
35 Hamza TH, van Houwelingen HC, Stijnen T. The binomial distribution of meta-analysis was preferred to model within-study variability. J Clin Epidemiol. 2008;61:41-51. [pmid: 18083461].
36 Riley RD, Abrams KR, Sutton AJ, Lambert PC, Thompson JR. Bivariate random-effects meta-analysis and the estimation of between-study correlation. BMC Med Res Methodol. 2007;7:3-3. [pmid: 17222330].
37 Hamza TH, Reitsma JB, Stijnen T. Meta-analysis of diagnostic studies: a comparison of random intercept, normal-normal, and binomial-normal bivariate summary ROC approaches. Med Decis Making. 2008;28:639-49. [pmid: 18753684].
38 Menke J. Bivariate random-effects meta-analysis of sensitivity and specificity with SAS PROC GLIMMIX. Methods Inf Med. 2010;49:54. [pmid: 19936437].
39 Scheidler J, Hricak H, Yu KK, Subak L, Segal MR. Radiological evaluation of lymph node metastases in patients with cervical cancer.A meta-analysis. JAMA. 1997;278:1096-101. [pmid: 9315770].
40 Hamza TH, Arends LR, van Houwelingen HC, Stijnen T. Multivariate random effects meta-analysis of diagnostic tests with multiple thresholds. BMC Med Res Methodol. 2009;9:73-73. [pmid: 19903336].
41 Bipat S, Zwinderman AH, Bossuyt PM, Stoker J. Multivariate random-effects approach: for meta-analysis of cancer staging studies. Acad Radiol. 2007;14:974-84. [pmid: 17659244].
42 Dukic V, Gatsonis C. Meta-analysis of diagnostic test accuracy assessment studies with varying number of thresholds. Biometrics. 2003;59:936-46. [pmid: 14969472].