# Methods

## Construction of a Database of Meta-Analysis Datasets

We used a previously described database of PubMed-indexed English-language meta-analyses of test accuracy (published between 1987 and 2003) to identify those that reported adequate information to reconstruct the 2×2 cross-classification of diagnoses and test results of included primary studies.12 This increased the efficiency of the data extraction process by avoiding the need to review all the primary papers included in each meta-analysis. The details of searches, abstract and full text screening methods, and selection criteria used to generate the original database are presented in a previous AHRQ report produced by the Tufts EPC.12 A list of included studies in provided in Appendix A.

From each meta-analysis we extracted the first author and year of publication, the number of included studies, and the number of index and reference standard tests reviewed. For each diagnostic outcome included in meta-analysis and each included study, we extracted the 2×2 table of true positive, false positive, true negative and false negative results, as defined by the original meta-analysis. We used these data to calculate descriptive statistics for the database, including descriptive statistics for the number of included studies in each meta-analysis, the number of patients in each component study, test sensitivity and specificity, and prevalence of the diagnostic outcomes of interest. We then repeated the meta-analyses using alternative statistical methods, as described below.

## Statistical Analyses

Meta-analyses of sensitivity and specificity aim to provide helpful summaries of the findings of individual studies. The point of average sensitivity and specificity is a useful summary when the results of the studies are relatively similar and the studied tests do not have different explicit thresholds for positive results. When studies have different explicit thresholds and their results range widely, though, a “summary line” that describes how sensitivity changes with specificity across studies may be a more informative description. In many cases, both summaries can be reasonably employed as they provide complementary information. Here we do not make any effort to choose the most helpful summary. We analyze all examples with all methods.

### Meta-Analysis of Sensitivity and Specificity (Summary Point)

#### Univariate Meta-Analysis Methods

We performed univariate meta-analyses of sensitivity and specificity to synthesize logit-transformed sensitivity and specificity values separately (i.e., ignoring their correlation) using fixed and random effects models weighting studies by the inverse of their sampling variance on the logit scale and assuming a normal sampling distribution. Between-study heterogeneity in random effects models was estimated using a non-iterative method (the DerSimonian-Laird moments-based estimator)24 and with an iterative method (restricted maximum likelihood; REML). We used a continuity correction of 0.5 for studies where the observed count was zero for any of the cells of the 2×2 table; the correction was applied to all four cells of such studies. We also performed univariate random effects analyses with the exact binomial likelihood using random effects logistic regression (a random intercept model). This model was also fit using maximum likelihood (ML) maximization.

#### Bivariate Meta-Analysis Methods

We fit bivariate random effects meta-analysis models that allow for correlation of sensitivity and specificity at the between-study level. These are hierarchical models that describe the observed variability using statistical distributions of data at two levels: a within-study-level and a between-study level. We fit two variants of the bivariate model to describe variation at the within-study level. The first used a normal approximation for the statistical distribution of 2×2 cell counts at the within-study level (for the logit-transformed sensitivities and specificities) and the second used the binomial distribution (exact likelihood) based on cell counts.

At the between-study level, both variants assumed that the (true) logit-transformed sensitivities and specificities followed a bivariate normal distribution centered at their summary estimates and with a covariance matrix that represented the between-studies component of the variability of the data. For the normal approximation variant of the model, we estimated the covariance matrix (equivalently, the correlation) using the non-iterative the estimator proposed by Jackson^e^ (a multivariate generalization of the DerSimonian-Laird model),25 as well as iteratively by REML.15 For the analysis using the exact binomial likelihood we used random effects logistic regression fit with ML.10,21 Because the log likelihood for this model has no closed form, it was approximated by numerical methods (adaptive Gaussian quadrature).26,27

e We refer to this method as “multivariate DerSimonian-Laird.”

The bivariate model with the exact binomial likelihood for within-study variability was also fit using a fully Bayesian approach, using non-informative prior distributions for parameters unspecified in the model. The model structure used for our analyses is presented in Appendix B. For each meta-analysis we ran 20,000 iterations and then assessed convergence by inspecting trace plots and calculating the Brooks-Gelman-Rubin statistic. We considered nodes to have converged when the Brooks-Gelman-Rubin statistic was less than 1.10. Additional iterations were run until convergence was achieved (if convergence was not reached after 20,000). To sample from the posterior distribution of parameters of interest we ran the model for an additional number of iterations equal to half the number that had been required to achieve convergence. From these posterior distributions we obtained the median and 95% central credibility intervals for parameters of interest. We assessed robustness to alternative prior distributions for the variance components and the between-study correlation of sensitivity and specificity (see Appendix B).

Table 1 summarizes the methods for meta-analysis of sensitivity and specificity assessed in this report. For parsimony, in the remainder of the report we refer to methods for model fitting using restricted (REML) or unrestricted maximum likelihood (ML) as “maximum likelihood estimation” (MLE) methods.

Table 1 Methods for meta-analysis of sensitivity and specificity used in this report

Modeling of Within-Study Variability | Meta-Analysis Method | Univariate Meta-Analysis (Estimation of Heterogeneity) | Bivariate Meta-Analysis (Estimation of Heterogeneity)
Approximate (normal for logit-transformed sensitivity, specificity) | Inverse variance | - Fixed effects; - Random effects (DL) | - Random effects (multivariate DL)^*^
Approximate (normal for logit-transformed sensitivity, specificity) | Likelihood maximization | - Random effects (REML) | - Random effects (REML)
Exact (binomial) | Likelihood maximization | - Random effects (ML) | - Random effects (ML); likelihood maximized by adaptive Gaussian quadrature
Exact (binomial) | Bayesian meta-analysis with non-informative priors | Not done | - Random effects (MCMC)

* Jackson generalization of the non-iterative DerSimonian and Laird method.

DL = DerSimonian-Laird; MCMC = Markov chain Monte Carlo; ML = maximum likelihood; REML = restricted maximum likelihood.

### Meta-Analytic SROC Curves (Summary Lines)

SROC curves depict graphically the relationship between sensitivity and specificity and provide a visual summary of overall test performance. These SROC curves summarize the trade-off between sensitivity and specificity across studies; they are distinct from ROC curves obtained in individual studies by varying the threshold over a continuous measurement or a predicted probability. The most commonly used method for generating meta-analytic SROC curves is that proposed by Moses and Littenberg, based on a regression of the difference of the logit-transformed sensitivity and specificity over their sum.8,9 We implemented both unweighted and weighted (by inverse of the variance of the diagnostic odds ratio) regressions for this method and compared results to the more theoretically motivated hierarchical regression methods (see below).

#### Hierarchical SROC (HSROC)

Rutter and Gatsonis proposed HSROC meta-analysis methods to address the limitations of the Moses-Littenberg SROC approach.13 As noted by Arends 2008^28^ several alternative parameterizations of the HSROC curve, in addition to the Rutter-Gatsonis model, can be produced from the bivariate meta-analysis model.13 These models represent alternative ways to describe the bivariate distribution of sensitivity and specificity, and can result in curves of different shape. We used the output of the bivariate meta-analysis model (fit both using maximum likelihood and Bayesian methods) to construct these curves, using methods described in the literature.28,29 Briefly, we estimated the intercept and slope of the ROC line (in logit space) based on: (a) regression of logit-sensitivity on logit-false positive rate; (b) regression of logit-false positive rate on logit-sensitivity; (c) regression of the difference of logit-sensitivity and logit-false positive rate on their sum); and (d) a major axis regression of logit-sensitivity on logit-false positive rate (a regression obtained by minimizing the distance between data points and the fitted line). Additional details about these models are presented in Appendix C.

### Comparisons Between Alternative Methods

We compared summary sensitivity, specificity and the width of the corresponding confidence (of credibility) intervals^f^ with scatter plots and histograms.31 We also graphed the ROC curves produced by the various methods and compared their results visually.

f For all bivariate analyses we obtained non-simultaneous confidence intervals for estimates of sensitivity and specificity. One could opt to obtain simultaneous confidence intervals30 instead; however this is not common practice in meta-analyses of test accuracy and has not been implemented in the existing software routines in common use. Generally, simultaneous confidence intervals tend to be wider than non-simultaneous confidence intervals.

With the exception of fixed effect univariate analyses, all other models used in this report assume that the study-specific parameters (sensitivity or specificity) are random effects (i.e., they differ by study). Most meta-analyses aim to generalize beyond the observed studies, and thus random effects models are appropriate. For this reason, we focus on random effects models in this report.

### Factors Associated With the Magnitude of Differences Between Methods

We hypothesized that the following meta-analysis level factors might be associated with differences in the summary estimates obtained from different methods: (1) the total number of included studies; (2) the median number of affected (for sensitivity) or unaffected (for specificity) participants (across studies in the meta-analysis); (3) the total number of studies in a meta-analysis where a cell of the 2×2 table (true positive or false negative for sensitivity; false positive or true negative for specificity) was zero.

We assessed whether these factors were associated with the magnitude of the difference between the following pairs of random effects meta-analyses: (1) univariate meta-analysis using REML with the normal within-study likelihood versus univariate meta-analysis using ML with the exact binomial likelihood; (2) bivariate meta-analysis using REML with normal within-study likelihood versus bivariate meta-analysis using ML with binomial within-study likelihood; (3) univariate meta-analysis using ML versus bivariate meta-analysis using ML, both with binomial within-study likelihood; (4) bivariate meta-analysis using ML versus bivariate meta-analysis using Bayesian methods, both with binomial within-study likelihood.

All comparisons were made on the logit scale, separately for estimates of sensitivity and specificity. The association between the factors of interest and the difference in estimates were evaluated using pairwise scatter plots and Spearman correlations (with associated p-values).

### Software

All non-Bayesian meta-analyses were performed in Stata/IC (version 12; Stata Corp., College Station, TX). Bayesian analyses were implemented in WinBugs32 (version 1.4.3; MRC Biostatistics Unit, Cambridge, UK), through calls from Stata or R (version 2.13.2; R Foundation for Statistical Computing, Vienna, Austria). Graphs were generated in Stata.