# Introduction

Medical tests are used every day for guiding diagnosis, predicting the future course of disease, and guiding treatment selection. The effects of tests on clinical outcomes are indirect, through their influence on physicians' diagnostic thinking and treatment decisionmaking.1 Comparative studies of testing versus no testing that can answer the overarching question of test effectiveness (clinical utility) are rarely performed. Because of this, assessment of medical tests often relies only on the evaluation of test “accuracy,”^a^ or test performance, typically measured by sensitivity and specificity (clinical validity of tests). Even when studies of clinical utility are available, systematic reviews of test performance are an important component of any comprehensive evidence assessment of a medical test.2,3

a Here we use the term “test accuracy” to denote “test performance.” We do not refer to the metric “accuracy.” which is the proportion of correct test classifications (true positives and true negatives) out of the total sample size in a study.

In most cases tests are used to classify patients into two mutually exclusive and exhaustive groups (“test positive” and “test negative”)—positive test results indicate that patients are more likely to have the condition of interest and should be targeted for additional diagnostic investigation or considered for therapeutic intervention.^b^ In such cases, test accuracy can be expressed as the ability to identify individuals with disease as “test positives” (sensitivity) and individuals with no disease as “test negatives” (specificity). Additional accuracy metrics, such as the area under the receiver operating characteristic (ROC) curve, the diagnostic odds ratio,4 or the Q* statistic (the point on the ROC curve where sensitivity equals specificity), are often reported in primary studies.5

b Although some tests produce ordinal classifications (e.g., high-intermediate-low probability of disease) or are used as components of more complex testing algorithms, the vast majority of systematic reviews and meta-analyses focus on binary classification.

Individual studies of test accuracy tend to be small and are often conducted in diverse settings. Systematic reviews of medical test studies offer a natural framework for evidence synthesis. When the aim is to increase precision or quantitatively assess the impact of study-level characteristics on test sensitivity or specificity, meta-analytic methods can be used to combine the results of independent studies into summary estimates of accuracy or to identify modifiers of accuracy through meta-regression.6,7

Meta-analysis of studies of test accuracy presents several challenges to systematic reviewers. First, meta-analysis of sensitivity and specificity requires modeling a multivariate outcome (sensitivity and specificity reported from each study).5 Second, joint modeling of sensitivity and specificity needs to take into account the correlation of these estimates across studies induced by threshold effects.8,9 Third, studies often produce heterogeneous results, necessitating the use of random effects models when the interest is to generalize beyond the observed data.10,11 Analyses that fail to take into account threshold effects or between-study variability may produce incompatible estimates of sensitivity and specificity or spuriously precise estimates of test accuracy.

In a previous empirical investigation,12 we found that the most common test performance metrics used in meta-analysis were sensitivity and specificity; in the majority of reviews only results from univariate analyses were reported. Additionally, many meta-analyses used the summary receiver characteristic operating (SROC) curve method proposed by Moses and Littenberg8,9 to assess test performance. This method is based on a regression of the difference of the logit-transformed sensitivity and specificity (i.e., the diagnostic log-odds ratio) on their sum. Although it allows for a between-study dependency between sensitivity and specificity, it is almost always implemented in a fixed effect framework. Furthermore, it ignores the exact binomial distributions of the test results among diseased and non-diseased individuals or the uncertainty in the measurement of the independent variable (the sum of the logit-sensitivity and logit-specificity) in the regression model. Recently, several authors have advocated using bivariate models based on hierarchical regression.10,13-15 These methods can be used to estimate summary sensitivity and specificity (i.e., a summary point on the ROC plane) or to fit a line describing the bivariate distribution of sensitivity and specificity (i.e., a hierarchical SROC curve). These meta-analysis models have now been implemented in major statistical packages16,17 and are becoming increasingly popular in meta-analytic practice.18 These implementations are based on maximization of likelihoods, but Bayesian methods have also been proposed.13,19,20 Limited empirical work suggests that these approaches yield similar conclusions in applied meta-analysis examples.17 Although theoretical arguments provide support for the use of bivariate random effects methods for the typical case of binary tests,^c^ the existing evidence on the practical implications of alternative methods is limited to small comparisons (typically based on a few meta-analysis examples).10,21,22 Some methodologists have suggested that “hierarchical models are necessary,”22 and others have conjectured that “differences between univariate and bivariate models […] may not be large.”23

c Similar arguments can be made in support of the use of extensions of these methods to account for multiple thresholds or multiple index tests; however, the majority of published meta-analyses are limited to the binary classification case. This report exclusively focuses on this most common case.

This report is the second in a series of three on meta-analysis of test accuracy, conducted by the Tufts Evidence-based Practice Center under contract with the Agency for Healthcare Research and Quality (AHRQ). For the current project we sought to perform a large-scale empirical comparison of alternative meta-analysis methods for sensitivity and specificity and for constructing SROC curves.^d^ This report addresses the following aims by using a previously established database of meta-analytic datasets:

d Other reports in this series include a comprehensive survey of methods and reporting in meta-analyses of test accuracy and the development of novel methods for the analysis of diagnostic test networks.

- Compare univariate (one outcome at a time) and bivariate (joint analysis of two outcomes) methods for meta-analysis of sensitivity and specificity.
- Compare inverse variance (DerSimonian-Laird), maximum likelihood (ML) and Bayesian methods for random effects meta-analysis of sensitivity and specificity.
- Compare methods using a normal approximation versus those using the exact binomial likelihood for meta-analysis of sensitivity and specificity.
- Compare alternative statistical models for constructing meta-analytic SROC curves.