# Discussion

## Key Findings

We present a comprehensive empirical comparison of meta-analytic methods for studies of test accuracy, both in terms of number of meta-analyses included and in terms of the scope of the meta-analytic methods considered. Univariate and bivariate meta-analyses most often resulted in similar point estimates, regardless of the estimation method (inverse variance or MLE) or the distribution used to model within-study variability (normal or exact binomial). Use of a normal approximation (both in univariate and bivariate meta-analyses) resulted in summary estimates with lower values and led to narrower confidence intervals, compared to methods that used the exact binomial likelihood. Although some of the differences between estimates were numerically large, their clinical importance is entirely context-specific. As expected, differences were larger in meta-analyses of small studies where continuity corrections (for the normal approximation) were needed for a large proportion of analyzed studies. Bivariate models fit using Bayesian and maximum likelihood methods produced almost identical summary estimates of sensitivity and specificity. The methods gave practically identical results in meta-analyses with moderate to large numbers of studies and when included studies had large sample sizes. The credibility intervals produced by Bayesian bivariate meta-analysis methods were substantially wider compared to the confidence intervals of maximum likelihood methods (using the exact binomial likelihood to describe within-study variability for both models). Although often not well estimated, the between-study correlation (of sensitivity and specificity) was frequently far from zero. This indicates that ignoring it is generally inappropriate for meta-analyses. Alternative meta-analytic methods to obtain SROC curves resulted in substantially different curves; differences were substantial between alternative parameterizations of the HSROC curves (particularly when the correlation between sensitivity and specificity was estimated to be positive).

### Meta-Analysis of Sensitivity and Specificity

Our findings substantially extend previous comparisons between methods for meta-analysis of test accuracy. Table 5 summarizes selected empirical comparisons of meta-analytic methods for test accuracy, where at least one of the methods allowed for correlation of sensitivity and specificity at the between-study level. Generally, previous reports have assessed only few applied meta-analysis examples (ranging from 1 to 50 meta-analyses), whereas we analyzed a much larger database using a wide array of analytic approaches.

Table 5 Summary of selected previous empirical comparisons of meta-analysis methods, including simulation studies

Author, Year | Number of MAs | Methods Compared and Model Fitting | Software | Key Findings | Authors' Recommendations/Conclusions
Macaskill17, 2004 | 1 (3 index tests) | HSROC [ML vs. fully Bayesian] vs. SROC (unweighted) | SAS | Estimates from ML analyses agree with Bayesian analyses; CIs from ML analysis were narrower than those from Bayesian analysis; the ROC curves for all analyses were similar for each index test. | ML formulation of HSROC model may be more accessible; Bayesian methods allow greater modeling flexibility; model checks are required for distributional assumptions of RE.
Reitsma10, 2005 | 1 (3 index tests) | SROC vs. BREMA normal | SAS | Summary values of sensitivity and specificity at the Q-point for one of the index tests were very different from the pooled estimate produced by the bivariate model. | The bivariate model is an “improvement and extension” of the “traditional” SROC approach. Explanatory variables with separate effects on sensitivity and specificity can be added in the bivariate model.
Chu & Cole21, 2006 | 1 | BREMA normal vs. binomial | SAS | Results of the two methods were similar in the applied example; in a limited simulation study the exact binomial likelihood gave unbiased results whereas the normal likelihood produced biased results for Se, Sp and ρ, when Se and Sp are close to 1. | In sparse datasets the exact likelihood may be preferable.
Harbord14, 2007 | 1 | Bivariate binomial vs. HSROC | SAS | Parameter estimates of each model can be used to calculate those of the other; results are nearly identical. In the single example, the correlation between sensitivity and specificity was positive. | The bivariate and HSROC models are closely related and in common situations identical. The HSROC model generally allows additional modeling flexibility.
Riley36, 2007 | 1 | Bivariate normal vs. univariate normal; univariate binomial vs. bivariate binomial (the latter failed to converge) | SAS | Univariate and bivariate analyses with a normal approximation produced similar point estimates; the correlation was estimated as -1, leading to slightly larger between-study variances in the bivariate analyses. The univariate analysis using the exact binomial likelihood produced slightly higher estimates of sensitivity and specificity; the corresponding bivariate analysis failed to converge. Simulation results indicated that the between-study correlation is often estimated to be -1 (or, less commonly, +1) when the number of studies is small or the within-study variance is large (compared to the between-study variance); this leads to an upward bias in the estimates of between-study variance in the bivariate case. In simulated bivariate meta-analyses of 10 studies the model using the binomial likelihood failed to converge in 397/1000 iterations. Multivariate meta-analysis methods allow borrowing strength across outcomes, particularly when data on some outcomes are missing at random. | The BREMA using a normal likelihood is preferable to two normal UREMAs. For meta-analyses of proportions (e.g., sensitivity and specificity) the exact binomial likelihood is preferable compared to the BREMA using a normal likelihood or two separate UREMAs using the exact likelihood. The bivariate model with the exact likelihood may occasionally fail to converge, often due to difficulties in estimating the correlation between sensitivity and specificity.
Arends28, 2008 | 2 | BREMA normal vs. binomial; alternative SROC curves derived from the bivariate model vs. the SROC method (Moses-Littenberg) | SAS | Results using the approximate normal likelihood were similar to those using the exact binomial likelihood in one example (however the exact likelihood produced higher values of sensitivity and specificity). The alternative SROC curves generated by the bivariate model differ substantially between them and may differ from the Moses-Littenberg SROC. | Multiple HSROC curves can be derived from the bivariate model. BREMA extends the SROC approach and provides a unifying framework for other approaches to the meta-analysis of diagnostic tests.
Hamza35, 2008 | 1 | UREMA, normal vs. binomial | SAS | In separate UREMA, estimates from the approximate normal method were lower compared to those produced from the exact binomial method, both for sensitivity and specificity. In simulation, the exact likelihood always performed better than the approximate approach and gave unbiased estimates; the approximate method had large bias and poor coverage. | The exact binomial likelihood is the method of preference and should be used whenever feasible.
Hamza37, 2008 | 1 | Random intercept SROC vs. BREMA (normal and binomial) | SAS | In the data example, the parameter estimates from the three methods differed substantially and resulted in substantially different SROC curves. In simulations, the BREMA with the exact binomial likelihood gave unbiased estimates of the intercept and slope parameter of the SROC; coverage was also acceptable except when the number of studies was low. The random intercept SROC method and the BREMA with a normal approximation produced biased results and had poor coverage probabilities. Bivariate methods may fail to converge when the correlation of sensitivity and specificity is close to -1 or +1. | The BREMA with exact binomial likelihood for the within-study model performed better than other methods.
Harbord22, 2008 | 8 | Pooling vs. univariate RE MA vs. separate MA of LRs (not considered here) vs. SROC (weighted and unweighted) vs. BREMA/HSROC | SAS | In 6/8 examples, all methods gave similar point estimates; in 2/8 cases pooling gave different point estimates; CIs from pooling were “too narrow”. In 5/8 examples, SROC curves from all methods (pooling not assessed) were similar; in 1 example the SROC results (weighted and unweighted) differed from other methods; in 1 example BREMA/HSROC, weighted SROC and separate RE MA produced different results from the unweighted SROC; in 1 example all methods produced similar results within the range of data but diverged outside that range. | HSROC or BREMA methods should be used as the standard; simple pooling should not be used to derive summary values of sensitivity and specificity; univariate RE MA may be used to give a valid estimate of the summary point alone; HSROC/BREMA appears to be the only way to obtain a valid SROC curve.
Chappell29, 2009 | 4 examples of an algorithm for deciding the optimal analysis method | Alternative SROC curves from the bivariate model; univariate vs. bivariate methods (fixed and random effects). BREMA estimates obtained from ML methods; interval estimates from the posterior distribution with seemingly non-informative priors for the hyperparameters through MCMC. | R | Multiple HSROC curves can be derived from the bivariate meta-analysis model; these curves can have substantially different shapes. Application of a proposed algorithm to guide the selection of the optimal meta-analysis model (bivariate versus univariate; fixed versus random) resulted in different choices (i.e. univariate meta-analyses were considered appropriate in some examples; bivariate in others). Parameters of the bivariate model were sometimes poorly estimated (particularly the between-study variances and the correlation of logit-sensitivity and specificity). | A zero or positive correlation between sensitivity and specificity “does not invalidate the bivariate model, as such,” but means that “the data should not be summarized by an SROC curve”. In some situations the SROC model may be inappropriate or there may not be enough data to estimate model parameters reliably. The authors propose an algorithm for the determination of the optimal analysis method for diagnostic test data.
Simel23, 2009 | 2 (one with 3 index tests) “selected for highlighting the merits” of BREMA + 5 unselected | BREMA normal vs. BREMA binomial vs. univariate analysis (fixed effects and RE) | SAS; Meta-Disc and CMA | In analyses selected for highlighting the merits” of BREMA: among pairwise comparisons between all methods the median difference was 1.5% (25^th^-75^th^ perc.=1.0-2.2%, maximum=6.0%); in 5 unselected analyses differences in sensitivity were 0-6%; differences in specificity were 0-2%; across all 7 examples the median difference in posterior probability (assuming a prior probability of 0.5) between methods was 2.5% (25^th^-75^th^ perc.=2.2–3.2%, maximum=11%). | The two approaches lead to relatively small differences in posterior probabilities; premature to insist that BREMA is the only way to get clinically useful results; more work needs to be done to solve the problem of non-convergence.
Paul19, 2010 | 1 | BREMA binomial [ML vs. Bayesian MCMC vs. Bayesian INLA vs. empirical Bayes INLA | R | In the applied example, point estimates and intervals around sensitivity, specificity and their variances were similar across methods. Bayesian methods and INLA with Empirical Bayes modeling produced similar point estimates and intervals around the correlation of sensitivity and specificity; the ML approach produced a different estimate of the correlation (-1) with very wide confidence intervals (-1 to 1). In a simulation study, INLA and ML methods produced similar results in terms of bias and mean squared error. INLA had better coverage; ML modeling underestimated the variance parameters whereas INLA produced less downwardly biased variance estimates and more, reliable estimates of the correlation. | INLA is more stable and gives generally better coverage probabilities for the pooled estimates and less biased estimates of variance parameters compared to ML modeling. INLA may be more user-friendly compared to full MCMC Bayesian modeling.
Menke38, 2010 19936437 | 50 | BREMA binomial vs. HSROC, both fixed and random effects | SAS | Estimates of BREMA and HSROC analyses were nearly identical; correlations between point estimates or SEs produced by the two methods were >0.99. Comparisons were not reported between random end fixed effects method; convergence was fast (1.4 seconds per MA). | Generalized linear random effects models are an alternative to the HSROC approach.
Verde20, 2010 | 2 | BREMA binomial using different specifications of the random effects distribution (binomial-normal vs. binomial-normal based on scale mixtures vs. binomial-t based on scale mixtures) and link functions (logit vs. c-log-log). Comparisons with the exact binomial BREMA model (from Chu & Cole 2006); the Rutter-Gatsonis HSROC model; and a Bayesian model accounting for disease prevalence were also reported for 1 of the examples. | R; Winbugs | The logit and c-log-log link functions produced similar results and comparable model fit. The binomial-normal and binomial-t (based on scale mixture of normals) models produced different results for the summary sensitivity and specificity (wider intervals for the bivariate-normal model) and their respective predictive distributions (wider intervals for the bivariate-t model with scale mixtures). The Bayesian bivariate-normal model produced similar results to the ML modeling. The Bayesian bivariate-t model with scale mixtures may offer better fit compared to the Bayesian bivariate-normal model with scale mixtures or the Bayesian bivariate-normal model. | Inference regarding random effects should be based on distributions more flexible than the normal. The predictive distribution of meta-analysis results reflects their future use. Model checking for meta-analysis results should not be ignored.

Note: Unless otherwise stated analyses used ML methods. The studies by Macaskill 17 2004; Reitsma10 2005; Chu & Cole21 2006; Harbord 14 2007; Chappell 2009^29^; Simel 23 2009; and Verde 2010 20, considered a common meta-analysis example, based on a systematic review by Scheidler 1997 39.

BREMA = bivariate random effects meta-analysis; CI = confidence interval; CMA = comprehensive meta-analysis; HSROC = hierarchical SROC; INLA = integrated nested Laplace approximations; LR = likelihood ratio; MA = meta-analysis; MCMC = Markov Chain Monte Carlo; ML = maximum likelihood; perc. = percentile; RE = random effect; Se = sensitivity; Sp = specificity; SROC = summary receiver operating characteristic curve; UREMA = univariate random effects meta-analyses.

Previous theoretical and simulation studies have suggested that the binomial distribution may be preferable to the normal approximation for modeling within-study variability. We believe that our observations are in concordance with this position. Not unexpectedly, the differences between the two methods were more pronounced in studies of small sample size and meta-analyses where tests had high sensitivity and specificity. In such cases the normal distribution will be a poor approximation to the binomial. Furthermore, in studies where some of the counts are zero, analysis using the normal likelihood will require the use of a continuity correction (so that the variance and point estimate of the study-level logit-sensitivity or logit-specificity can be calculated). The continuity correction will bias the point estimate of individual studies; this is why the difference in the summary estimates between methods that rely on the normal approximation versus those that do not is greater when the summary sensitivity or specificity are closer to one35. An additional reason for the systematically smaller summary sensitivity or specificity with normal approximation methods may be that in the meta-analysis, the estimate (logit-transformed sensitivity or specificity) and its variance are correlated, in that the variance is a function of the estimate and the sample size. This correlation is positive for proportions larger than 0.5, and thus estimates near one have larger variance (and receive less weight in the meta-analysis) compared to estimates near 0.5. The net effect is that summary sensitivity or specificity are biased towards 0.5.^28,33^ Such a bias is not a problem for meta-analysis methods using the exact likelihood, and is not observed when variance-stabilizing transformations are used for meta-analysis of proportions (such as the arcsine transformation).

We found that univariate and bivariate meta-analysis methods produced generally similar summary estimates and marginal confidence intervals for sensitivity and specificity. Differences are likely to be more pronounced when evaluating linear combinations of the estimates (e.g., the sum of sensitivity and specificity) particularly in problems of higher dimensionality (e.g., multiple index tests applied to the same patients and compared against a common reference standard). This issue is addressed in detail in a separate report of diagnostic tests in preparation by the EPC.

Few studies have compared the results of bivariate meta-analysis using maximum likelihood versus fully Bayesian methods for the meta-analysis of sensitivity and specificity and those that did used models that were not directly comparable).17,19,20 Many investigators have commented that Bayesian methods are less accessible to meta-analysts than the corresponding maximum likelihood methods. We provide the BUGS code we used to fit the bivariate model for the model in Appendix B. We found that convergence problems were not common when fitting the bivariate model; when present they were mostly due to numerical instability in cases where the number of studies was small, sensitivity and specificity were close to 1, or the between-study variance was very low. For Bayesian analyses, we were able to obtain model convergence in most datasets by slightly modifying the non-informative prior distributions used. Bayesian analyses resulted in summary estimates of sensitivity and specificity that were very close to those obtained from the maximum likelihood estimation. However, there were substantial differences in the width of the credibility and confidence intervals produced by Bayesian and maximum likelihood analyses, respectively.

Bivariate methods provide estimates of the correlation between sensitivity and specificity at the between-study level. Alternative models (normal approximation for within-study variability versus exact binomial distribution) and estimation methods (non-iterative versus MLE; frequentist versus Bayes) can yield quite different correlation estimates. This may be another symptom of the fact that the correlation parameter is generally poorly estimated. A telling observation is the following: frequentist approaches (maximum likelihood and inverse variance methods) often estimated the correlation parameter in the extremes of its domain, namely -1 (and sometimes +1). Riley 2007 made a similar observation in a simulation study.36 In contrast, Bayesian methods rarely produced extreme correlation values, due to shrinkage toward the mean of the prior distribution (the mean is zero for the uniform (-1,1) prior distribution that we used).

### Constructing Meta-Analytic ROC Curves

Arguably, ROC curves provide additional information compared to meta-analytic estimates of sensitivity and specificity, because they illustrate the relationship between sensitivity and specificity. Based on our previous survey the most commonly used method for constructing SROC curves is the approach proposed by Moses and Littenberg.12 Despite its popularity this model has several shortcomings, including its failure to account for underlying binomial distribution of data, between-study heterogeneity, and measurement error on its independent variable. These shortcomings of the Moses-Littenberg SROC model are overcome by the hierarchical modeling approaches, including the increasingly used model proposed by Rutter and Gatsonis.13 It can been shown that the Rutter-Gatsonis HSROC model is equivalent to the bivariate meta-analysis of sensitivity and specificity, in the absence of covariates in the regression.14,28 Thus, the parameters of the HSROC model can be “back-calculated” using estimates from the bivariate meta-analysis model (an approach we followed in this report).

The Rutter-Gatsonis HSROC model is one of several possible parameterization of the HSROC curve. Arends 2008^28^ discuss alternative parameterizations, which we implemented for all meta-analyses we performed (plots available from the authors upon request). These parameterizations often result in substantially different curves compared to the one produced by the Rutter-Gatsonis HSROC model.13,29 Importantly, in some cases the slope of the ROC curve is not always positive (in contrast to the Rutter-Gatsonis method) and, therefore, the relationship between sensitivity and specificity cannot be explained by threshold effects across studies. Based on this, Chappell et al. determine that SROC curves are not always a helpful summary of the data, and propose a stepwise algorithm for determining the most appropriate approach to summarize accuracy studies.29

## Limitations

Some limitations need to be considered when interpreting our results. Because of the way we constructed the database of systematic reviews of test accuracy, all included meta-analyses were conducted prior to 2003 and were published in English-language journals. Although this may limit the clinical applicability of their actual findings, it does not substantially affect the conclusions of our empirical comparison of methods because the datasets included are very diverse in terms of number of included studies, sample size, and reported test accuracy (Table 1). In a recent comprehensive review of reporting and design characteristics of systematic reviews of test accuracy that gave quantitative synthesis results (covering meta-analyses published up to 2010), we found no substantial change over time in the number of included studies or the number of meta-analyses conducted per review article.12

Another limitation of our work is that many systematic reviews contributed multiple datasets to the empirical comparison (approximately two datasets per review, on average). We believe that the effect of this clustering is probably minor because in most cases when multiple meta-analyses are presented in the same systematic review, they typically address different index or reference standard tests (often based on nonoverlapping sets of primary studies). Unfortunately, data to explore the potential effect of such clustering are typically not available in meta-analyses or primary diagnostic test studies. Nonetheless, our approach can be considered representative of current practice in applied meta-analyses, where pairs of tests and diagnostic outcomes are almost always evaluated one at a time.

Finally we have focused on meta-analysis of sensitivity, specificity and meta-analytic ROC curves, but did not consider other metrics such as likelihood ratios, odds ratios or areas under the ROC curve. We note that these metrics can be derived from the methods we assess (for example, likelihood ratios can be estimated from the output of the bivariate model) and are generally less commonly used in the diagnostic literature.