# Alternative Parameterizations of the Hierarchical Summary Receiver Operating Characteristic Curve

We followed Arends 2008 [25] in constructing alternative hierarchical summary receiver operating (HSROC) curves based on the bivariate random effects meta-analysis model. Here, η̄ is the summary logit-transformed true positive rate, ξ̄ is the summary logit-transformed false positive rate (1 – specificity), η_i_ and ξ_i_ are respectively the logit-transformed true positive rate and the false positive rate in the i-th study; σ_η_^2^ and σ_ξ_^2^ are the variances of the logit-transformed true and false positive rates, respectively; σ_ξη_ is their covariance.

After fitting the bivariate model, we obtained the HSROC lines, as shown in Table C-1.

Table C-1 Alternative HSROC lines

Model | Regression line | Intercept | Slope
η ∼ ξ regression | η_i_ = η¯ + (σ_ξ_η__)/(σ_ξ_^2^) ( ξ_i_ − ξ¯ ) | η¯ − (σ_ξ_η__)/(σ_ξ_^2^) ξ¯ | (σ_ξ_η__)/(σ_ξ_^2^)
ξ ∼ η regression | η_i_ = η¯ + (σ_η_^2^)/(σ_ξ_η__) ( ξ_i_ − ξ¯ ) | η¯ − (σ_η_^2^)/(σ_ξ_η__) ξ¯ | (σ_η_^2^)/(σ_ξ_η__)
D ∼ S regression | η_i_ = η¯ + (σ_η_^2^ + σ_ξ_η__)/(σ_ξ_^2^ + σ_ξ_η__) ( ξ_i_ − ξ¯ ) | η¯ − (σ_η_^2^ + σ_ξ_η__)/(σ_ξ_^2^ + σ_ξ_η__) ξ¯ | (σ_η_^2^ + σ_ξ_η__)/(σ_ξ_^2^ + σ_ξ_η__)
Rutter-Gatsonis model | η_i_ = η¯ + (σ_η_)/(σ_ξ_) ( ξ_i_ − ξ¯ ) | η¯ − (σ_η_)/(σ_ξ_) ξ¯ | (σ_η_)/(σ_ξ_)
MAR | η_i_ = η¯ + (σ_η_^2^ − σ_ξ_^2^ + sqrt(( σ_η_^2^ − σ_ξ_^2^ )^2^ + 4 σ_ξ η_^2^))/(2 σ_ξ_η__) ( ξ_i_ − ξ¯ ) | η¯ − (σ_η_^2^ − σ_ξ_^2^ + sqrt(( σ_η_^2^ − σ_ξ_^2^ )^2^ + 4 σ_ξ η_^2^))/(2 σ_ξ_η__) ξ¯ | (σ_η_^2^ − σ_ξ_^2^ + sqrt(( σ_η_^2^ − σ_ξ_^2^ )^2^ + 4 σ_ξ η_^2^))/(2 σ_ξ_η__)

D = logit(sensitivity) – logit(1-specificity)

S = logit(sensitivity) + logit(1-specificity)

MAR = major axis regression

η = logit(sensitivity)

ξ = logit(1-specificity).

“Intercept” and “slope” refer to the estimated intercept and slope of the hsROC in the logit space. They describe a line that can be transformed to the HSROC curve. For each model, the corresponding hsROC curve is represented by the following function: sensitivity = invlogit(intercept + slope * logit(specificity)). Estimates of the intercept and slope can be derived from the output of the bivariate regression model in all major statistical packages.