# Bayesian Model for Bivariate Meta-Analysis of Sensitivity and Specificity

For each study we used the 2×2 table of test results (positive or negative) and true disease status (Table B-1).

Table B-1 2×2 table of test results

| | Disease status
| | Disease | Healthy
Test result | Positive | TP | FP
Test result | Negative | FN | TN

Here, TP, FP, FN, and TN are respectively the counts of true positive, false positive, false negative, and true negative findings from each study. The accuracy metrics of interest were the logit-transformed sensitivity and false positive rate (=1-specificity); at the study-level these were estimated as η̂ = logit ( (TP)/(TP + FN) ) , and ξ̂ = logit ( (FP)/(FP + TN) ) , respectively.

Throughout the report, we use the logit transformation of a proportion (p): logit ( p ) = ln ( (p)/(1 − p) ) . The inverse-logit of any number (x) is then defined as logit^− 1^ ( x ) = (exp ( x ))/(1 + exp ) ( x )) .

## Bivariate meta-analysis of sensitivity and specificity

The within studies model is specified as TP_i_ ∼ Bin (D_i_, logit^−1^(η_i_)) and FP_i_ ∼ Bin(H_i_, logit^−1^(ξ_i_)), where D_i_ and H_i_ are the total numbers of affected and unaffected individuals, respectively, for the i-th study. We then model the “true” logit-transformed true positive rate (η_i_) and false positive rate (ξ_i_) of the i-th study as drawn from a bivariate normal distribution: ( η_i_ ξ_i_ ) ∼ N ( ( η¯ ξ¯ ) , Ω ) . Here, η̄ and ξ̄ are the “summary” logit-transformed summary true and false positive rate (across studies), with covariance matrix Ω = ( σ_η_^2^ ρ σ_η_ σ_ξ_ ρ σ_η_ σ_ξ_ σ_ξ_^2^ ) ; σ_η_^2^ and σ_ξ_^2^ are the variances of the logit-transformed sensitivity and false positive rate, respectively; ρ is their correlation (at the between-study level); and ρσ_η_σ_ξ_ is their covariance.

This model was used both for the maximum likelihood and the Bayesian bivariate meta-analyses. The key difference between the two approaches is that in the latter, the model parameters (e.g., the average true and false positive rates and the covariance matrix) are treated as random variables and prior distributions need to be specified for them (hyper-priors). For the average logit-transformed true and false positive rates we used vague normal priors N(0,100); for the between-study variance we assumed that its square root (i.e., the standard deviation) followed a uniform prior distribution U(0.01,5). Finally, we assumed that the within study correlation had a uniform prior distribution U(−1,1). We used alternative prior distributions both for the variances and the correlation. One set of analyses used a normal prior N^0,25^ for the Fisher-transformed correlation coefficient across studies (as suggested in Paul et al, Statistics in Medicine, 2010). Another set of analyses used a Wishart prior for the covariance matrix (as suggested in Verde et al., Statistics in Medicine 2010).

## BUGS language Bayesian model for bivariate meta-analysis of sensitivity and false positive rate

#BUGS model: bivariate meta-analysis of test accuracy
#exact binomial likelihood for within-study variability

model {
for( i in 1: n_studies) {
tp[i] ∼ dbin(tpr[i], n1[i])
fp[i] ∼ dbin(fpr[i], n2[i])
logit(tpr[i]) <- m[i,1]
logit(fpr[i]) <- m[i,2]
m[i,1:2] ∼ dmnorm(mu0[1:2], sigma.inv[1:2, 1:2])
}
# Priors for means
mu0[1] ∼ dnorm(0, 0.01)
mu0[2] ∼ dnorm(0, 0.01)

#priors for the elements of the covariance matrix
sigma.inv[1:2, 1:2] <- inverse(sigma[1:2,1:2])
sigma[1,1] <- sigma1*sigma1
sigma[1,2] <- sigma1*sigma2*rho
sigma[2,1] <- sigma1*sigma2*rho
sigma[2,2] <- sigma2*sigma2
sigma1 ∼ dunif(0.01,5)
sigma2 ∼ dunif(0.01,5)
rho ∼ dunif(-1, 1)

# Pooled summaries
x.pool <- mu0[1]
y.pool <- mu0[2]
poolse <- exp(x.pool)/(1 + exp(x.pool))
poolsp <- 1 - exp(y.pool)/(1 + exp(y.pool))

# Variance-covariance matrix for random-effects
sigmaSens <- sigma[1,1]
sigmaSpec <- sigma[2,2]
}