# Included Studies

1 Arbyn M, Schenck U, Ellison E, et al. Metaanalysis of the accuracy of rapid prescreening relative to full screening of pap smears. Cancer. Feb. 25. 2003;99(1):9-16. [pmid: 12589640].
2 Bachmann LM, Kolb E, Koller MT, et al. Accuracy of Ottawa ankle rules to exclude fractures of the ankle and mid-foot: systematic review. BMJ. Feb. 22. 2003;326(7386):417. [pmid: 12595378].
3 Badgett RG, Lucey CR, Mulrow CD. Can the clinical examination diagnose left-sided heart failure in adults?. JAMA. Jun. 4. 1997;277(21):1712-9. [pmid: 9169900].
4 Bafounta ML, Beauchet A, Aegerter P, et al. Is dermoscopy (epiluminescence microscopy) useful for the diagnosis of melanoma? Results of a meta-analysis using techniques adapted to the evaluation of diagnostic tests. Arch Dermatol. Oct. 2001;137(10):1343-50. [pmid: 11594860].
5 Bailey JJ, Berson AS, Handelsman H, et al. Utility of current risk stratification tests for predicting major arrhythmic events after myocardial infarction. J Am Coll Cardiol. Dec. 2001;38(7):1902-11. [pmid: 11738292].
6 Balk EM, Ioannidis JP, Salem D, et al. Accuracy of biomarkers to diagnose acute cardiac ischemia in the emergency department: a meta-analysis. Ann Emerg Med. May. 2001;37(5):478-94. [pmid: 11326184].
7 Barnes CJ, Pietrobon R, Higgins LD. Does the pulse examination in patients with traumatic knee dislocation predict a surgical arterial injury? A meta-analysis. J Trauma. Dec. 2002;53(6):1109-14. [pmid: 12478036].
8 Bax JJ, Wijns W, Cornel JH, et al. Accuracy of currently available techniques for prediction of functional recovery after revascularization in patients with left ventricular dysfunction due to chronic coronary artery disease: comparison of pooled data. J Am Coll Cardiol. Nov. 15. 1997;30(6):1451-60. [pmid: 9362401].
9 Bax JJ, Poldermans D, Elhendy A, et al. Sensitivity, specificity, and predictive accuracies of various noninvasive techniques for detecting hibernating myocardium. Curr Probl Cardiol. Feb. 2001;26(2):147-86. [pmid: 11276916].
10 Berger MY, van d V, Lijmer JG, et al. Abdominal symptoms: do they predict gallstones? A systematic review. Scand J Gastroenterol. Jan. 2000;35(1):70-6. [pmid: 10672838].
11 Bonis PA, Ioannidis JP, Cappelleri JC, et al. Correlation of biochemical response to interferon alfa with histological improvement in hepatitis C: a meta-analysis of diagnostic test characteristics. Hepatology. Oct. 1997;26(4):1035-44. [pmid: 9328332].
12 Brown DL, Doubilet PM. Transvaginal sonography for diagnosing ectopic pregnancy: positivity criteria and performance characteristics. J Ultrasound Med. Apr. 1994;13(4):259-66. [pmid: 7932989].
13 Brown MD, Rowe BH, Reeves MJ, et al. The accuracy of the enzyme-linked immunosorbent assay D-dimer test in the diagnosis of pulmonary embolism: a meta-analysis. Ann Emerg Med. Aug. 2002;40(2):133-44. [pmid: 12140491].
14 Brown MD, Lau J, Nelson RD, et al. Turbidimetric D-dimer test in the diagnosis of pulmonary embolism: a metaanalysis. Clin Chem. Nov. 2003;49(11):1846-53. [pmid: 14578316].
15 Carlson KJ, Skates SJ, Singer DE. Screening for ovarian cancer. Ann Intern Med. Jul. 15. 1994;121(2):124-32. [pmid: 8017726].
16 Carter BG, Butt W. Review of the use of somatosensory evoked potentials in the prediction of outcome after severe brain injury. Crit Care Med. Jan. 2001;29(1):178-86. [pmid: 11176182].
17 Chappell ET, Moure FC, Good MC. Comparison of computed tomographic angiography with digital subtraction angiography in the diagnosis of cerebral aneurysms: a meta-analysis. Neurosurgery. Mar. 2003;52(3):624-31. [pmid: 12590688].
18 Cher DJ, Conwell JA, Mandel JS. MRI for detecting silicone breast implant rupture: meta-analysis and implications. Ann Plast Surg. Oct. 2001;47(4):367-80. [pmid: 11601570].
19 Chien PF, Khan KS, Ogston S, et al. The diagnostic accuracy of cervico-vaginal fetal fibronectin in predicting preterm delivery: an overview. Br J Obstet Gynaecol. Apr. 1997;104(4):436-44. [pmid: 9141580].
20 Chien PF, Arnott N, Gordon A, et al. How useful is uterine artery Doppler flow velocimetry in the prediction of pre-eclampsia, intrauterine growth retardation and perinatal death? An overview. BJOG. Feb. 2000;107(2):196-208. [pmid: 10688503].
21 Chin AS, Goldman LE, Eisenberg MJ. Functional testing after coronary artery bypass graft surgery: a meta-analysis. Can J Cardiol. Jun. 2003;19(7):802-8. [pmid: 12813614].
22 Clark TJ, Mann CH, Shah N, et al. Accuracy of outpatient endometrial biopsy in the diagnosis of endometrial hyperplasia. Acta Obstet Gynecol Scand. Sep. 2001;80(9):784-93. [pmid: 11531627].
23 Clarke CE, Davies P. Systematic review of acute levodopa and apomorphine challenge tests in the diagnosis of idiopathic Parkinson's disease. J Neurol Neurosurg Psychiatry. Nov. 2000;69(5):590-4. [pmid: 11032609].
24 Colin C, Lanoir D, Touzet S, et al. Sensitivity and specificity of third-generation hepatitis C virus antibody detection assays: an analysis of the literature. J Viral Hepat. Mar. 2001;8(2):87-95. [pmid: 11264728].
25 Conde-Agudelo A, Kafury-Goeta AC. Triple-marker test as screening for Down syndrome: a meta-analysis. Obstet Gynecol Surv. Jun. 1998;53(6):369-76. [pmid: 9618713].
26 Contopoulos-Ioannidis DG, Ioannidis JP. Maternal cell-free viremia in the natural history of perinatal HIV-1 transmission: a meta-analysis. J Acquir Immune Defic Syndr Hum Retrovirol. Jun. 1. 1998;18(2):126-35. [pmid: 9637577].
27 Cook DJ, Fitzgerald JM, Guyatt GH, et al. Evaluation of the protected brush catheter and bronchoalveolar lavage in the diagnosis of nosocomial pneumonia. J Intensive Care Med. Jul. 1991;6(4):196-205. [pmid: 10147949].
28 Dales RE, Stark RM, Raman S. Computed tomography to stage lung cancer. Approaching a controversy using meta-analysis. Am Rev Respir Dis. May. 1990;141(5 Pt 1):1096-101. [pmid: 2160211].
29 de Albuquerque FL, Picano E. Comparison of dipyridamole and exercise stress echocardiography for detection of coronary artery disease (a meta-analysis). Am J Cardiol. May. 15. 2001;87(10):1193-6. [pmid: 11356397].
30 de Bernardinis, Violi V, Roncoroni L, et al. Discriminant power and information content of Ranson's prognostic signs in acute pancreatitis: a meta-analytic study. Crit Care Med. Oct. 1999;27(10):2272-83. [pmid: 10548220].
31 de Jaeger, Litalien C, Lacroix J, et al. Protected specimen brush or bronchoalveolar lavage to diagnose bacterial nosocomial pneumonia in ventilated adults: a meta-analysis. Crit Care Med. Nov. 1999;27(11):2548-60. [pmid: 10579279].
32 de Vries SO, Hunink MG, Polak JF. Summary receiver operating characteristic curves as a technique for meta-analysis of the diagnostic performance of duplex ultrasonography in peripheral arterial disease. Acad Radiol. Apr. 1996;3(4):361-9. [pmid: 8796687].
33 Delgado-Bolton RC, Fernandez-Perez C, Gonzalez-Mate A, et al. Meta-analysis of the performance of 18F-FDG PET in primary tumor detection in unknown primary tumors. J Nucl Med. Aug. 2003;44(8):1301-14. [pmid: 12902422].
34 Detrano R, Janosi A, Lyons KP, et al. Factors affecting sensitivity and specificity of a diagnostic test: the exercise thallium scintigram. Am J Med. Apr. 1988;84(4):699-710. [pmid: 3041808].
35 Deville WL, van der Windt DA, Dzaferagic A, et al. The test of Lasegue: systematic review of the accuracy in diagnosing herniated discs. Spine. May. 1. 2000;25(9):1140-7. [pmid: 10788860].
36 Dijkhuizen FP, Mol BW, Brolmann HA, et al. The accuracy of endometrial sampling in the diagnosis of patients with endometrial carcinoma and hyperplasia: a meta-analysis. Cancer. Oct. 15. 2000;89(8):1765-72. [pmid: 11042572].
37 Dove SB. Radiographic diagnosis of dental caries. J Dent Educ. Oct. 2001;65(10):985-90. [pmid: 11700001].
38 Dwamena BA, Sonnad SS, Angobaldo JO, et al. Metastases from non-small cell lung cancer: mediastinal staging in the 1990s--meta-analytic comparison of PET and CT. Radiology. Nov. 1999;213(2):530-6. [pmid: 10551237].
39 Ebell MH, Flewelling D, Flynn CA. A systematic review of troponin T and I for diagnosing acute myocardial infarction. J Fam Pract. Jun. 2000;49(6):550-6. [pmid: 10923557].
40 Ebell MH, White LL, Weismantel D. A systematic review of troponin T and I values as a prognostic tool for patients with chest pain. J Fam Pract. Aug. 2000;49(8):746-53. [pmid: 10947143].
41 Engels EA, Terrin N, Barza M, et al. Meta-analysis of diagnostic tests for acute sinusitis. J Clin Epidemiol. Aug. 2000;53(8):852-62. [pmid: 10942869].
42 Engman ML. An update on EBCT (Ultrafast CT) scans for coronary artery disease. J Insur Med. 1998;30(3):175-9. [pmid: 10351178].
43 Fahey MT, Irwig L, Macaskill P. Meta-analysis of Pap test accuracy. Am J Epidemiol. Apr. 1. 1995;141(7):680-9. [pmid: 7702044].
44 Faron G, Boulvain M, Irion O, et al. Prediction of preterm delivery by fetal fibronectin: a meta-analysis. Obstet Gynecol. Jul. 1998;92(1):153-8. [pmid: 9649113].
45 Farquhar C, Ekeroma A, Furness S, et al. A systematic review of transvaginal ultrasonography, sonohysterography and hysteroscopy for the investigation of abnormal uterine bleeding in premenopausal women. Acta Obstet Gynecol Scand. Jun. 2003;82(6):493-504. [pmid: 12780419].
46 Fleischmann KE, Hunink MG, Kuntz KM, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA. Sep. 9. 1998;280(10):913-20. [pmid: 9739977].
47 Fraile M, Rull M, Julian FJ, et al. Sentinel node biopsy as a practical alternative to axillary lymph node dissection in breast cancer patients: an approach to its validity. Ann Oncol. Jun. 2000;11(6):701-5. [pmid: 10942059].
48 Gianrossi R, Detrano R, Colombo A, et al. Cardiac fluoroscopy for the diagnosis of coronary artery disease: a meta analytic review. Am Heart J. Nov. 1990;120(5):1179-88. [pmid: 2146867].
49 Gill CJ, Lau J, Gorbach SL, et al. Diagnostic accuracy of stool assays for inflammatory bacterial gastroenteritis in developed and resource-poor countries. Clin Infect Dis. Aug. 1. 2003;37(3):365-75. [pmid: 12884161].
50 Gisbert JP, Pajares JM. Diagnosis of Helicobacter pylori infection by stool antigen determination: a systematic review. Am J Gastroenterol. Oct. 2001;96(10):2829-38. [pmid: 11693315].
51 Glas AS, Roos D, Deutekom M, et al. Tumor markers in the diagnosis of primary bladder cancer. A systematic review. J Urol. Jun. 2003;169(6):1975-82. [pmid: 12771702].
52 Goodman CM, Cohen V, Thornby J, et al. The life span of silicone gel breast implants and a comparison of mammography, ultrasonography, and magnetic resonance imaging in detecting implant rupture: a meta-analysis. Ann Plast Surg. Dec. 1998;41(6):577-85. [pmid: 9869129].
53 Gordon I, Barkovics M, Pindoria S, et al. Primary vesicoureteric reflux as a predictor of renal damage in children hospitalized with urinary tract infection: a systematic review and meta-analysis. J Am Soc Nephrol. Mar. 2003;14(3):739-44. [pmid: 12595511].
54 Gould MK, Maclean CC, Kuschner WG, et al. Accuracy of positron emission tomography for diagnosis of pulmonary nodules and mass lesions: a meta-analysis. JAMA. Feb. 21. 2001;285(7):914-24. [pmid: 11180735].
55 Gould MK, Kuschner WG, Rydzak CE, et al. Test performance of positron emission tomography and computed tomography for mediastinal staging in patients with non-small-cell lung cancer: a meta-analysis. Ann Intern Med. Dec. 2. 2003;139(11):879-92. [pmid: 14644890].
56 Greco S, Girardi E, Masciangelo R, et al. Adenosine deaminase and interferon gamma measurements for the diagnosis of tuberculous pleurisy: a meta-analysis. Int J Tuberc Lung Dis. Aug. 2003;7(8):777-86. [pmid: 12921155].
57 Hallan S, Asberg A. The accuracy of C-reactive protein in diagnosing acute appendicitis--a meta-analysis. Scand J Clin Lab Invest. Aug. 1997;57(5):373-80. [pmid: 9279962].
58 Harvey RT, Gefter WB, Hrung JM, et al. Accuracy of CT angiography versus pulmonary angiography in the diagnosis of acute pulmonary embolism: evaluation of the literature with summary ROC curve analysis. Acad Radiol. Oct. 2000;7(10):786-97. [pmid: 11048876].
59 Hobby JL, Tom BD, Bearcroft PW, et al. Magnetic resonance imaging of the wrist: diagnostic performance statistics. Clin Radiol. Jan. 2001;56(1):50-7. [pmid: 11162698].
60 Hoffman RM, Clanon DL, Littenberg B, et al. Using the free-to-total prostate-specific antigen ratio to detect prostate cancer in men with nonspecific elevations of prostate-specific antigen levels. J Gen Intern Med. Oct. 2000;15(10):739-48. [pmid: 11089718].
61 Honest H, Bachmann LM, Gupta JK, et al. Accuracy of cervicovaginal fetal fibronectin test in predicting risk of spontaneous preterm birth: systematic review. BMJ. Aug. 10. 2002;325(7359):301. [pmid: 12169504].
62 Hoogendam A, Buntinx F, de Vet HC. The diagnostic value of digital rectal examination in primary care screening for prostate cancer: a meta-analysis. Fam Pract. Dec. 1999;16(6):621-6. [pmid: 10625141].
63 Hrung JM, Sonnad SS, Schwartz JS, et al. Accuracy of MR imaging in the work-up of suspicious breast lesions: a diagnostic meta-analysis. Acad Radiol. Jul. 1999;6(7):387-97. [pmid: 10410164].
64 Huicho L, Campos M, Rivera J, et al. Fecal screening tests in the approach to acute infectious diarrhea: a scientific overview. Pediatr Infect Dis J. Jun. 1996;15(6):486-94. [pmid: 8783344].
65 Huicho L, Campos-Sanchez M, Alamo C. Metaanalysis of urine screening tests for determining the risk of urinary tract infection in children. Pediatr Infect Dis J. Jan. 2002;21(1):1-11. 88. [pmid: 11791090].
66 Hurley JC. Concordance of endotoxemia with gram-negative bacteremia. A meta-analysis using receiver operating characteristic curves. Arch Pathol Lab Med. Aug. 2000;124(8):1157-64. [pmid: 10923076].
67 Imran MB, Khan MA, Aslam MN, et al. Diagnosis of coronary artery disease by stress echocardiography and perfusion scintigraphy. J Coll Physicians Surg Pak. Aug. 2003;13(8):465-70. [pmid: 12921688].
68 Ioannidis JP, Salem D, Chew PW, et al. Accuracy and clinical effect of out-of-hospital electrocardiography in the diagnosis of acute cardiac ischemia: a meta-analysis. Ann Emerg Med. May. 2001;37(5):461-70. [pmid: 11326182].
69 Jensen JE, Nielsen SH, Foged L, et al. The MICRAL test for diabetic microalbuminuria: predictive values as a function of prevalence. Scand J Clin Lab Invest. Apr. 1996;56(2):117-22. [pmid: 8743103].
70 Jorgensen K, Andersen TJ, Dam H. The diagnostic efficiency of the Rorschach Depression Index and the Schizophrenia Index: a review. Assessment. Sep. 2000;7(3):259-80. [pmid: 11037393].
71 Jorm AF. Methods of screening for dementia: a meta-analysis of studies comparing an informant questionnaire with a brief cognitive test. Alzheimer Dis Assoc Disord. Sep. 1997;11(3):158-62. [pmid: 9305501].
72 Kardaun JW, Kardaun OJ. Comparative diagnostic performance of three radiological procedures for the detection of lumbar disk herniation. Methods Inf Med. Jan. 1990;29(1):12-22. [pmid: 2308524].
73 Kearon C, Julian JA, Newman TE, et al. Noninvasive diagnosis of deep venous thrombosis. McMaster Diagnostic Imaging Practice Guidelines Initiative. Ann Intern Med. Apr. 15. 1998;128(8):663-77. [pmid: 9537941].
74 Kellen M, Aronson S, Roizen MF, et al. Predictive and diagnostic tests of renal failure: a review. Anesth Analg. Jan. 1994;78(1):134-42. [pmid: 8267149].
75 Kertai MD, Boersma E, Bax JJ, et al. A meta-analysis comparing the prognostic accuracy of six diagnostic tests for predicting perioperative cardiac risk in patients undergoing major vascular surgery. Heart. Nov. 2003;89(11):1327-34. [pmid: 14594892].
76 Kinkel K, Hricak H, Lu Y, et al. US characterization of ovarian masses: a meta-analysis. Radiology. Dec. 2000;217(3):803-11. [pmid: 11110947].
77 Kittler H, Pehamberger H, Wolff K, et al. Diagnostic accuracy of dermoscopy. Lancet Oncol. Mar. 2002;3(3):159-65. [pmid: 11902502].
78 Klassen TP, Rowe PC. Selecting diagnostic tests to identify febrile infants less than 3 months of age as being at low risk for serious bacterial infection: a scientific overview. J Pediatr. Nov. 1992;121(5 Pt 1):671-6. [pmid: 1432412].
79 Koelemay MJ, Lijmer JG, Stoker J, et al. Magnetic resonance angiography for the evaluation of lower extremity arterial disease: a meta-analysis. JAMA. Mar. 14. 2001;285(10):1338-45. [pmid: 11255390].
80 Koumans EH, Johnson RE, Knapp JS, et al. Laboratory testing for Neisseria gonorrhoeae by recently introduced nonculture tests: a performance review with clinical and public health considerations 15. Clin Infect Dis. Nov. 1998;27(5):1171-80. [pmid: 9827265].
81 Kowalski J, Tu XM, Jia G, et al. A comparative meta-analysis on the variability in test performance among FDA-licensed enzyme immunosorbent assays for HIV antibody testing. J Clin Epidemiol. May. 2001;54(5):448-61. [pmid: 11337207].
82 Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. Mar. 1. 1999;83(5):660-6. [pmid: 10080415].
83 Lensing AW, Hirsh J. 125I-fibrinogen leg scanning: reassessment of its role for the diagnosis of venous thrombosis in post-operative patients. Thromb Haemost. Jan. 11. 1993;69(1):2-7. [pmid: 8446932].
84 LeSar CJ, Meier GH, DeMasi RJ, et al. The utility of color duplex ultrasonography in the diagnosis of temporal arteritis. J Vasc Surg. Dec. 2002;36(6):1154-60. [pmid: 12469046].
85 Lewis JD, Ng K, Hung KE, et al. Detection of proximal adenomatous polyps with screening sigmoidoscopy: a systematic review and meta-analysis of screening colonoscopy. Arch Intern Med. Feb. 24. 2003;163(4):413-20. [pmid: 12588199].
86 Li J. Capnography alone is imperfect for endotracheal tube placement confirmation during emergency intubation 16. J Emerg Med. Apr. 2001;20(3):223-9. [pmid: 11267809].
87 Liberman M, Sampalis F, Mulder DS, et al. Breast cancer diagnosis by scintimammography: a meta-analysis and review of the literature. Breast Cancer Res Treat. Jul. 2003;80(1):115-26. [pmid: 12889605].
88 Littenberg B, Mushlin AI. Technetium bone scanning in the diagnosis of osteomyelitis: a meta-analysis of test performance. Diagnostic Technology Assessment Consortium. J Gen Intern Med. Mar. 1992;7(2):158-64. [pmid: 1487763].
89 Maas JW, Evers JL, ter RG, et al. Pregnancy rate following normal versus abnormal hysterosalpingography findings: a meta-analysis. Gynecol Obstet Invest. 1997;43(2):79-83. [pmid: 9067711].
90 Mackenzie R, Palmer CR, Lomas DJ, et al. Magnetic resonance imaging of the knee: diagnostic performance studies. Clin Radiol. Apr. 1996;51(4):251-7. [pmid: 8617036].
91 Makrydimas G, Sotiriadis A, Ioannidis JP. Screening performance of first-trimester nuchal translucency for major cardiac defects: a meta-analysis. Am J Obstet Gynecol. Nov. 2003;189(5):1330-5. [pmid: 14634564].
92 Mantha S, Roizen MF, Barnard J, et al. Relative effectiveness of four preoperative tests for predicting adverse cardiac outcomes after vascular surgery: a meta-analysis. Anesth Analg. Sep. 1994;79(3):422-33. [pmid: 8067544].
93 Mijnhout GS, Hoekstra OS, van Tulder MW, et al. Systematic review of the diagnostic accuracy of (18)F-fluorodeoxyglucose positron emission tomography in melanoma patients. Cancer. Apr. 15. 2001;91(8):1530-42. [pmid: 11301402].
94 Mirvis SE, Shanmuganathan K, Miller BH, et al. Traumatic aortic injury: diagnosis with contrast-enhanced thoracic CT--five-year experience at a major trauma center. Radiology. Aug. 1996;200(2):413-22. [pmid: 8685335].
95 Mitchell MF, Schottenfeld D, Tortolero-Luna G, et al. Colposcopy for the diagnosis of squamous intraepithelial lesions: a meta-analysis. Obstet Gynecol. Apr. 1998;91(4):626-31. [pmid: 9540955].
96 Mitchell MF, Cantor SB, Ramanujam N, et al. Fluorescence spectroscopy for diagnosis of squamous intraepithelial lesions of the cervix. Obstet Gynecol. Mar. 1999;93(3):462-70. [pmid: 10075001].
97 Mol BW, Dijkman B, Wertheim P, et al. The accuracy of serum chlamydial antibodies in the diagnosis of tubal pathology: a meta-analysis. Fertil Steril. Jun. 1997;67(6):1031-7. [pmid: 9176440].
98 Mol BW, Bayram N, Lijmer JG, et al. The performance of CA-125 measurement in the detection of endometriosis: a meta-analysis. Fertil Steril. Dec. 1998;70(6):1101-8. [pmid: 9848302].
99 Mol BW, Lijmer JG, Ankum WM, et al. The accuracy of single serum progesterone measurement in the diagnosis of ectopic pregnancy: a meta-analysis. Hum Reprod. Nov. 1998;13(11):3220-7. [pmid: 9853884].
100 Mol BW, Meijer S, Yuppa S, et al. Sperm penetration assay in predicting successful in vitro fertilization. A meta-analysis. J Reprod Med. 1998;43:503-8. [pmid: 9653696].
101 Nallamothu BK, Saint S, Bielak LF, et al. Electron-beam computed tomography in the diagnosis of coronary artery disease: a meta-analysis. Arch Intern Med. Mar. 26. 2001;161(6):833-8. [pmid: 11268225].
102 Nelemans PJ, Leiner T, de Vet HC, et al. Peripheral arterial disease: meta-analysis of the diagnostic performance of MR angiography. Radiology. Oct. 2000;217(1):105-14. [pmid: 11012430].
103 Ng PC, Dear PR. The predictive value of a normal ultrasound scan in the preterm baby--a meta-analysis. Acta Paediatr Scand. Mar. 1990;79(3):286-91. [pmid: 2139756].
104 Oei EH, Nikken JJ, Verstijnen AC, et al. MR imaging of the menisci and cruciate ligaments: a systematic review. Radiology. Mar. 2003;226(3):837-48. [pmid: 12601211].
105 Oei SG, Helmerhorst FM, Keirse MJ. When is the post-coital test normal? A critical appraisal. Hum Reprod. Jul. 1995;10(7):1711-4. [pmid: 8582966].
106 Olaniyan OB. Validity of colposcopy in the diagnosis of early cervical neoplasia--a review. Afr J Reprod Health. Dec. 2002;6(3):59-69. [pmid: 12685410].
107 Olatidoye AG, Wu AH, Feng YJ, et al. Prognostic role of troponin T versus troponin I in unstable angina pectoris for cardiac events with meta-analysis comparing published studies. Am J Cardiol. Jun. 15. 1998;81(12):1405-10. [pmid: 9645888].
108 Orr RK, Porter D, Hartman D. Ultrasonography to evaluate adults for appendicitis: decision making based on meta-analysis and probabilistic reasoning. Acad Emerg Med. Jul. 1995;2(7):644-50. [pmid: 8521213].
109 Pai M, Flores LL, Pai N, et al. Diagnostic accuracy of nucleic acid amplification tests for tuberculous meningitis: a systematic review and meta-analysis. Lancet Infect Dis. Oct. 2003;3(10):633-43. [pmid: 14522262].
110 Palomaki GE, Neveux LM, Haddow JE. Can reliable Down's syndrome detection rates be determined from prenatal screening intervention trials?. J Med Screen. 1996;3(1):12-7. [pmid: 8861045].
111 Patel SR, Wiese W, Patel SC, et al. Systematic review of diagnostic tests for vaginal trichomoniasis. Infect Dis Obstet Gynecol. 2000;8(5-6):248-57. [pmid: 11220487].
112 Patrick DL, Cheadle A, Thompson DC, et al. The validity of self-reported smoking: a review and meta-analysis. Am J Public Health. Jul. 1994;84(7):1086-93. [pmid: 8017530].
113 Paulson WD, Ram SJ, Birk CG, et al. Does blood flow accurately predict thrombosis or failure of hemodialysis synthetic grafts? A meta-analysis. Am J Kidney Dis. Sep. 1999;34(3):478-85. [pmid: 10469858].
114 Petersen JR, Smith E, Okorodudu AO, et al. Comparison of four methods (L/S ratio, TDx FLM, lamellar bodies, PG) for fetal lung maturity using meta-analysis. Clin Lab Manage Rev. Mar. 1996;10(2):169-75. [pmid: 10172601].
115 Picano E, Bedetti G, Varga A, et al. The comparable diagnostic accuracies of dobutamine-stress and dipyridamole-stress echocardiographies: a meta-analysis. Coron Artery Dis. Mar. 2000;11(2):151-9. [pmid: 10758817].
116 Rao JK, Weinberger M, Oddone EZ, et al. The role of antineutrophil cytoplasmic antibody (c-ANCA) testing in the diagnosis of Wegener granulomatosis. A literature review and meta-analysis. Ann Intern Med. Dec. 15. 1995;123(12):925-32. [pmid: 7486487].
117 Reed JF III. Meta-analysis of the reliability of noninvasive carotid studies. Biomed Instrum Technol. Nov. 1991;25(6):465-71. [pmid: 1838017].
118 Revah A, Hannah ME, Sue AQA. Fetal fibronectin as a predictor of preterm birth: an overview. Am J Perinatol. 1998;15(11):613-21. [pmid: 10064202].
119 Romagnuolo J, Bardou M, Rahme E, et al. Magnetic resonance cholangiopancreatography: a meta-analysis of test performance in suspected biliary disease. Ann Intern Med. Oct. 7. 2003;139(7):547-57. [pmid: 14530225].
120 Rosado B, Menzies S, Harbauer A, et al. Accuracy of computer diagnosis of melanoma: a quantitative meta-analysis. Arch Dermatol. Mar. 2003;139(3):361-7. [pmid: 12622631].
121 Rosenberg D, Cretin S. Use of meta-analysis to evaluate tolonium chloride in oral cancer screening. Oral Surg Oral Med Oral Pathol. May. 1989;67(5):621-7. [pmid: 2654801].
122 Samson DJ, Flamm CR, Pisano ED, et al. Should FDG PET be used to decide whether a patient with an abnormal mammogram or breast finding at physical examination should undergo biopsy?. Acad Radiol. Jul. 2002;9(7):773-83. [pmid: 12139091].
123 Sarmiento OL, Weigle KA, Alexander J, et al. Assessment by meta-analysis of PCR for diagnosis of smear-negative pulmonary tuberculosis. J Clin Microbiol. Jul. 2003;41(7):3233-40. [pmid: 12843069].
124 Scheidler J, Hricak H, Yu KK, et al. Radiological evaluation of lymph node metastases in patients with cervical cancer. A meta-analysis. JAMA. Oct. 1. 1997;278(13):1096-101. [pmid: 9315770].
125 Schinkel AF, Bax JJ, Geleijnse ML, et al. Noninvasive evaluation of ischaemic heart disease: myocardial perfusion imaging or stress echocardiography?. Eur Heart J. May. 2003;24(9):789-800. [pmid: 12727146].
126 Scholten RJ, Deville WL, Opstelten W, et al. The accuracy of physical diagnostic tests for assessing meniscal lesions of the knee: a meta-analysis. J Fam Pract. Nov. 2001;50(11):938-44. [pmid: 11711009].
127 Scholten RJ, Opstelten W, van der Plas CG, et al. Accuracy of physical diagnostic tests for assessing ruptures of the anterior cruciate ligament: a meta-analysis. J Fam Pract. Sep. 2003;52(9):689-94. [pmid: 12967539].
128 Schreiber G, McCrory DC. Performance characteristics of different modalities for diagnosis of suspected lung cancer: summary of published evidence. Chest. Jan. 2003;123(1 Suppl):115S-28S. [pmid: 12527571].
129 Schwimmer J, Essner R, Patel A, et al. A review of the literature for whole-body FDG PET in the management of patients with melanoma. Q J Nucl Med. Jun. 2000;44(2):153-67. [pmid: 10967625].
130 Siegman-Igra Y, Anglim AM, Shapiro DE, et al. Diagnosis of vascular catheter-related bloodstream infection: a meta-analysis. J Clin Microbiol. Apr. 1997;35(4):928-36. [pmid: 9157155].
131 Silvestri GA, Littenberg B, Colice GL. The clinical evaluation for detecting metastatic lung cancer. A meta-analysis. Am J Respir Crit Care Med. Jul. 1995;152(1):225-30. [pmid: 7599828].
132 Skupski DW, Rosenberg CR, Eglinton GS. Intrapartum fetal stimulation tests: a meta-analysis. Obstet Gynecol. Jan. 2002;99(1):129-34. [pmid: 11777523].
133 Smart SC, Sagar KB. Diagnostic and prognostic use of stress echocardiography in stable patients. Echocardiography. Jul. 2000;17(5):465-77. [pmid: 10979024].
134 Smith-Bindman R, Hosmer W, Feldstein VA, et al. Second-trimester ultrasound to detect fetuses with Down syndrome: a meta-analysis. JAMA. Feb. 28. 2001;285(8):1044-55. [pmid: 11209176].
135 Sonnad SS, Langlotz CP, Schwartz JS. Accuracy of MR imaging for staging prostate cancer: a meta-analysis to examine the effect of technologic change. Acad Radiol. Feb. 2001;8(2):149-57. [pmid: 11227643].
136 Stengel D, Bauwens K, Sehouli J, et al. Systematic review and meta-analysis of emergency ultrasonography for blunt abdominal trauma. Br J Surg. Jul. 2001;88(7):901-12. [pmid: 11442520].
137 Swart P, Mol BW, van d V, et al. The accuracy of hysterosalpingography in the diagnosis of tubal pathology: a meta-analysis. Fertil Steril. Sep. 1995;64(3):486-91. [pmid: 7641899].
138 Tan KT, van Beek EJ, Brown PW. Magnetic resonance angiography for the diagnosis of renal artery stenosis: a meta-analysis. Clin Radiol. Jul. 2002;57(7):617-24. [pmid: 12096862].
139 Tebas P, Nease RF, Storch GA. Use of the polymerase chain reaction in the diagnosis of herpes simplex encephalitis: a decision analysis model. Am J Med. Oct. 1998;105(4):287-95. [pmid: 9809689].
140 Tsao H, Nadiminti U, Sober AJ, et al. A meta-analysis of reverse transcriptase-polymerase chain reaction for tyrosinase mRNA as a marker for circulating tumor cells in cutaneous melanoma. Arch Dermatol. Mar. 2001;137(3):325-30. [pmid: 11255333].
141 Urbach DR, Khajanchee YS, Jobe BA, et al. Cost-effective management of common bile duct stones: a decision analysis of the use of endoscopic retrograde cholangiopancreatography (ERCP), intraoperative cholangiography, and laparoscopic bile duct exploration. Surg Endosc. Jan. 2001;15(1):4-13. [pmid: 11178753].
142 van Beek EJ, Brouwers EM, Song B, Bongaerts AH, Oudkerk M. Lung scintigraphy and helical computed tomography for the diagnosis of pulmonary embolism: a meta-analysis. Clin Appl Thromb Hemost. 2001;7:87-92. [pmid: 11292198].
143 van Gelder JM. Computed tomographic angiography for detecting cerebral aneurysms: implications of aneurysm size distribution for the sensitivity, specificity, and likelihood ratios. Neurosurgery. Sep. 2003;53(3):597-605. [pmid: 12943576].
144 Varonen H, Makela M, Savolainen S, et al. Comparison of ultrasound, radiography, and clinical examination in the diagnosis of acute maxillary sinusitis: a systematic review. J Clin Epidemiol. Sep. 2000;53(9):940-8. [pmid: 11004420].
145 Vasbinder GB, Nelemans PJ, Kessels AG, et al. Diagnostic tests for renal artery stenosis in patients suspected of having renovascular hypertension: a meta-analysis. Ann Intern Med. Sep. 18. 2001;135(6):401-11. [pmid: 11560453].
146 Vasquez TE, Rimkus DS, Hass MG, et al. Efficacy of morphine sulfate-augmented hepatobiliary imaging in acute cholecystitis. J Nucl Med Technol. Sep. 2000;28(3):153-5. [pmid: 11001495].
147 Visser K, Hunink MG. Peripheral arterial disease: gadolinium-enhanced MR angiography versus color-guided duplex US--a meta-analysis. Radiology. Jul. 2000;216(1):67-77. [pmid: 10887229].
148 Watson EJ, Templeton A, Russell I, et al. The accuracy and efficacy of screening tests for Chlamydia trachomatis: a systematic review. J Med Microbiol. Dec. 2002;51(12):1021-31. [pmid: 12466399].
149 Wellnitz U, Binder B, Fritz P, et al. Reliability of telepathology for frozen section service. Anal Cell Pathol. 2000;21(3-4):213-22. [pmid: 11339570].
150 Wells PS, Lensing AW, Davidson BL, et al. Accuracy of ultrasound for the diagnosis of deep venous thrombosis in asymptomatic patients after orthopedic surgery. A meta-analysis. Ann Intern Med. Jan. 1. 1995;122(1):47-53. [pmid: 7985896].
151 White RH, McGahan JP, Daschbach MM, et al. Diagnosis of deep-vein thrombosis using duplex ultrasound. Ann Intern Med. Aug. 15. 1989;111(4):297-304. [pmid: 2667418].
152 Whitsel EA, Boyko EJ, Siscovick DS. Reassessing the role of QTc in the diagnosis of autonomic failure among patients with diabetes: a meta-analysis. Diabetes Care. Feb. 2000;23(2):241-7. [pmid: 10868838].
153 Wiese W, Patel SR, Patel SC, et al. A meta-analysis of the Papanicolaou smear and wet mount for the diagnosis of vaginal trichomoniasis. Am J Med. Mar. 2000;108(4):301-8. [pmid: 11014723].
154 Wijnberger LD, Huisjes AJ, Voorbij HA, et al. The accuracy of lamellar body count and lecithin/sphingomyelin ratio in the prediction of neonatal respiratory distress syndrome: a meta-analysis. BJOG. Jun. 2001;108(6):583-8. [pmid: 11426891].
155 Williams JW Jr., Noel PH, Cordes JA, Ramirez G, Pignone M. Is this patient clinically depressed?. JAMA.
156 Wu AH, Lane PL. Metaanalysis in clinical chemistry: validation of cardiac troponin T as a marker for ischemic heart diseases. Clin Chem. Aug. 1995;41(8 Pt 2):1228-33. [pmid: 7628112].
157 Zandbergen EG, de Haan RJ, Stoutenbeek CP, et al. Systematic review of early prediction of poor outcome in anoxic-ischaemic coma. Lancet. Dec. 5. 1998;352(9143):1808-12. [pmid: 9851380].