# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BREMA: bivariate random effects meta-analysis
EPC: Evidence-based Practice Center
FPR: false positive rate
HSROC: hierarchical summary receiver operating characteristic
MAR: major axis regression
ML: maximum likelihood
MLE: maximum likelihood estimation
REML: restricted maximum likelihood
ROC: receiver operating characteristic
SROC: summary receiver operating characteristic
TPR: true positive rate