# Results

In consultation with our Working Group, we developed a framework to assist in the evaluation of potential confounding in observational studies in systematic reviews (Figure 1). This framework builds on existing routine processes of systematic reviews: developing a scope of work, establishing study selection criteria to inform literature searches and selection of studies for abstraction, developing abstraction and assessment tools, abstracting and analyzing data, assessing the risk of bias and confounding, synthesizing the evidence, and conducting strength of evidence (SOE) assessment. In Figure 1, the central column describes routine tasks required for all systematic reviews in Steps A through E. Methodological guidance is available at length elsewhere on these steps and is not repeated here.5,28,32-35 The inclusion of observational studies requires additional tasks, highlighted in the right-hand column of the figure and described in detail below. The process described below is simplified to apply to a single outcome. Reviews that evaluate multiple outcomes may need to replicate these steps for each outcome.

Figure 1 Process framework assessing the validity of causal links for observational study evidence in systematic reviews

Figure 1 is a flow chart that describes the overall steps of a systematic review and additional steps needed for systematic reviews that include observational studies to assess the validity of causal links. It highlights 5 steps for systematic reviews. Step A is to develop the scope of work for the systematic review; Step B is to establish study selection criteria to inform literature searches and screen the yield for inclusion; Step C is to develop abstraction and assessment tools; Step D is to abstract and analyze data, assess risk of bias and confounding, and synthesize the evidence; and Step E is to conduct strength of evidence (SOE) assessment. The inclusion of observational studies requires additional tasks that are described at length the section titled “Results.” These additional tasks include: expanding the analytic framework to include sources of confounding (for observational studies that meet causal inference threshold); identifying sources of bias specific to each included observational study design; identifying potential sources of confounding specific to each included study design; assessing individual studies for risk of design-specific sources of bias; assessing individual studies for controls for potential confounders; and considering competing hypotheses for observational bodies of evidence.

## Expand the Analytic Framework To Consider Sources of Confounding

The Working Group noted the importance of specifying possible sources of confounding at the start of the review (Step A). As shown in Step B, the analytic framework should clearly show potential confounders that could affect the relationship between the choice of intervention and the outcome. In the likely absence of empirical evidence that specific confounders altered estimates of effect, systematic reviewers may need to rely on hypothesized relationships to lay out potential relationships between the confounder, the intervention, and the outcome.19 Not all confounders need to be controlled in every study and the use of causal diagrams may help explicate which sets of confounders could alter the effect estimate in an individual study.36

The specific sources of confounding will vary based on the clinical context. Some of these sources of confounding can be controlled for in the design or analysis of the study. The potential for uncontrolled confounding in an overall body of evidence may influence what systematic reviewers judge to be admissible study designs. Current EPC guidance on the inclusion of observational studies suggests that reviewers consider two questions: (1) Are there gaps in the evidence from RCTs? (2) Will observational studies provide valid and useful information?7

Norris et al. suggest considering the clinical context and natural history of a condition when judging whether observational studies are likely to produce estimates that are too biased to provide valid and useful information.7 With fluctuating conditions, for instance, patients may improve spontaneously, making it difficult to attribute improvements to treatments through evaluations based on observational studies. Norris et al. note the importance of selection bias and confounding by indication (confounding that results from the patient having a specific indication that influences both the selection of the intervention and the outcome) as particular problems plaguing observational studies but do not offer thresholds for when anticipated concerns from bias would preclude the consideration of these studies. We believe, as do other commentators, that one standard cannot be established across all clinical areas and each review requires an understanding of the threats to validity for that topic.

## Identify the Source of Bias and Confounding Specific to Each Included Design

In Step C of the process framework, prior to the review of individual studies, systematic reviewers would consider the observational study designs that could potentially be included in the review, and risks of bias and confounding that are likely to be a concern in the body of evidence.

Based on discussions with the Working Group, we changed the orientation of some of the questions in the item bank so that all of the questions now focus on whether a solution to a bias concern in a study was adequate. This shifts the burden for the reviewer from determining whether the study was “good” (lower risk of bias) to identifying salient problems with the study's approach (higher risk of bias). For example, one question was changed from “Did the study apply inclusion/exclusion criteria uniformly to all comparison groups/arms of the study?” to “Do the inclusion/exclusion criteria vary across the comparison groups of the study?”

Also based on discussions with the Working Group, we eliminated one question from the item bank (“Is the study design prospective, retrospective, or mixed?”) prior to conducting the voting exercise. Working Group members found this design classification to be problematic and uninformative because it does not indicate whether an outcome is assessed according to predictable criteria or whether it was specified in a protocol.

In addition to group discussions, three of the six members of the Working Group participated in one round of testing of the instrument and one member provided comments on item bank questions outside the formal exercise. Table 1 presents the results of the testing and identifies questions that were considered very important or somewhat important by at least two of the three participants, with the exception of questions on precision because precision (the absence of random error) is independent of risk of bias (systematic error). Of the 16 questions, 5 were not considered important or very important across study designs by at least two of the three Working Group members. However, because of the small number of participants, we do not recommend deleting the five questions and instead note Working Group members' concerns and comments on the item bank questions.

Table 1 Questions from the item bank Working Group voting participants^a^ considered very or somewhat important for evaluating risk of bias and precision by observational study design type

Item Bank | | Case Series | Case-Control | Cohort | Cross-sectional
Questions to assess the risk of bias
Q1 | Do the inclusion/exclusion criteria vary across the comparison groups of the study? | X^b^ | X | X | X
Q2 | Does the strategy for recruiting participants into the study differ across groups? | X^b^ | X | X | X
Q3 | Is the selection of the comparison group inappropriate, after taking into account feasibility and ethical considerations? | | X | X | X
Q4 | Does the study fail to account for variations in the execution of the study from the proposed protocol?
Q5 | Was the outcome assessor not blinded to the intervention or exposure status of participants? | · | | X | X
Q6 | Were valid and reliable measures, implemented consistently across all study participants used to assess inclusion/exclusion criteria, intervention/exposure outcomes, participant health benefits and harms, and confounding? | X | X | X | X
Q7 | Was the length of followup different across study groups? | X^b^ | | X
Q8 | In cases of high loss to followup (or differential loss to followup), was the impact assessed (e.g., through sensitivity analysis or other adjustment method)? | | | X
Q9 | Are any important primary outcomes missing from the results?
Q10 | Are any important harms or adverse events that may be a consequence of the intervention/exposure missing from the results?
Q11 | Are results believable taking study limitations into consideration?
Questions to assess confounding
Q6 | Were valid and reliable measures, implemented consistently across all study participants used to assess inclusion/exclusion criteria, intervention/exposure outcomes, participant health benefits and harms, and confounding? | X | X | X | X
Q12 | Any attempt to balance the allocation between the groups or match groups (e.g., through stratification, matching, propensity scores)? | X | X | X | X
Q13 | Were the important confounding variables taken into account in the design and/or analysis (e.g., through matching, stratification, interaction terms, multivariate analysis, or other statistical adjustment such as instrumental variables)? | | X | X | X
Questions to assess precision
Q14 | Is the sample size insufficiently large to detect a clinically significant difference of 5% or more between groups in at least one primary outcome measure?
Q15 | Are the statistical methods used to assess the primary benefit outcomes inadequate? | X | X | X | X
Q16 | Are the statistical methods used to assess the main harm or adverse event outcomes inadequate? | X | X | X | X

a At least two out of three respondents.

b Questions can be answered for case series without a uniform set of eligibility criteria, recruitment strategy, or length of followup for all participants.

One of the Working Group members considered Question 4, concerning whether the study failed to account for variation in execution from the proposed protocol, as unlikely to be reliable because the information was rarely available and also thought that the question did not distinguish between major and minor variations from the protocol. Questions 9 and 10, concerning outcomes missing from the results (benefits and harms), were considered evidence of reporting bias and so outside the scope of the risk of bias assessment. One Working Group member thought that Question 11, concerning whether results were believable after taking study limitations into consideration, expressed weak logic that would result in unexpected findings being discounted. Lastly, several Working Group members expressed concerns about Question 14, which relates to precision. One Working Group member thought that a post hoc power calculation to determine the sufficiency of sample size was no longer needed and that reviewers could instead adopt the GRADE Working Group's guidance on optimal information size. GRADE guidance states that a study (body of evidence) is precise if it includes more than 400 events.37

By type of study design, the resulting item bank (see Table 1) includes the following number of questions considered very or somewhat important by the subset of Working Group members, out of the full bank of 16 questions: case series (8), case-control (8), cohort (12), and cross-sectional (10).

Working Group members favored retaining two questions that measured confounding in individual studies: the use of valid and reliable measures of confounding (all study designs) and important confounding variables taken into account in the design and/or analysis (all designs except case series; Table 2).

Table 2 Questions and instructions in revised RTI Item Bank following voting exercise by category of bias or precision assessed

Questions From Item Bank [Instructions for principal investigator (PI) and/or abstractor] | | Type of Bias Assessed
Q1 | Do the inclusion/exclusion criteria vary across the comparison groups of the study? [PI: Drop question if not relevant to all included studies. To use this question for studies with one group, the focus of the question on comparison groups and related response categories would need to be changed to individuals.] | Selection bias
Q2 | Does the strategy for recruiting participants into the study differ across groups? [PI: Drop question if not relevant to all included studies. If the recruitment strategy results in pre-intervention differences in prognostic factors that could explain the selection of the intervention and the outcome, confounding can occur. If the strategy results in the selective and differential inclusion of patients (such as prevalent rather than new users), selection bias can occur. To use this question for studies with one group, the focus of the question on comparison groups and related response categories would need to be changed to individuals.] | Selection bias confounding
Q3 | Is the selection of the comparison group inappropriate? [PI: Provide instruction to the abstractor based on the type of study. Interventions with community components are likely to have contamination if all groups are drawn from the same community. Interventions without community components should select groups from the same source (e.g., community or hospital) to reduce baseline differences across groups. For case-control studies, controls should represent the population from which cases arose; that is, controls should have met the case definition if they had the outcome.] | Selection bias, confounding
Q4 | Does the study fail to account for important variations in the execution of the study from the proposed protocol? [PI: Consider intensity, duration, frequency, route, setting, and timing of intervention/exposures. Drop if not relevant for body of literature.] | Performance bias
Q5 | Was the assessor not blinded to the outcome, exposure, or intervention status of the participants? [PI: Clinical assessors may not always be blinded to exposure/intervention as well as outcome status. For studies where patients are selected based on outcome (e.g., case-control), blinding to exposure or intervention status is particularly important. For designs where patients are selected based on exposure status (e.g., cohorts), blinding to outcomes is particularly important. Drop if not relevant to the body of literature.] | Detection bias
Q6 | Were valid and reliable measures not used or not implemented consistently across all study participants to assess inclusion/exclusion criteria, intervention/exposure outcomes, participant benefits and harms, and potential confounders? [PI: Important measures should be identified for abstractors and if there is more than one, they should be listed separately. PI may need to establish a threshold for what would constitute acceptable measures based on study topic. When subjective or objective measures could be collected, the PI will need to consider if subjective measures based on self-report should be considered as being less reliable and valid than objective measures such as clinical reports and lab findings. Some characteristics may require that sources for establishing their validity and/or reliability be described or referenced. If so, provide instruction to abstractors.] | Detection bias, confounding
Q7 | Was the length of followup different across study groups? [Abstractor: When followup was the same for all study participants, the answer is no. If different lengths of followup were adjusted by statistical techniques, (e.g., survival analysis), the answer is no. Studies in which differences in followup were ignored should be answered yes.] | Attrition bias
Q8 | In cases of missing data (e.g., overall or differential loss to followup for cohort studies or missing exposure data for case-control studies), was the impact not assessed (e.g., through sensitivity analysis or other adjustment method)? [PI: For cohort studies, attrition is measured in relation to the time between baseline (allocation in some instances) and outcome measurement for both retrospective and prospective studies and could include data loss from switching. Attrition rates may vary by outcome and time of measurement. Specify the criterion to meet relevant standards for the topic. Specify measurement period of interest, if repeated measures. For case-control studies, evaluate missing data in relation to exposure status.] | Attrition bias, detection bias
Q9 | Are any important primary outcomes missing from the results? [PI: Identify all primary outcomes that one would expect to be reported in the study, including timing of measurement.] | Selective outcome reporting
Q10 | Are any important harms or adverse events that may be a consequence of the intervention/exposure missing from the results? [PI: Identify all important harms that one would expect be reported in the study, including timing of measurement. Drop if not relevant to body of literature.] | Selective outcome reporting
Q11 | Did the study fail to balance the allocation between the groups or match groups (e.g., through stratification, matching, propensity scores)? [PI: Drop if not relevant to the body of evidence.] | Confounding
Q12 | Were important confounding variables not taken into account in the design and/or analysis (e.g., through matching, stratification, interaction terms, multivariate analysis, or other statistical adjustment such as instrumental variables)? [PI: Provide instruction to abstractors on known confounding variables and inadequate adjustment for confounding for each outcome.] | Confounding
Q13 | Are results believable taking study limitations into consideration? [Abstractor: This question is intended to capture the overall quality of the study. Consider issues that may limit your ability to interpret the results of the study. Review responses to earlier questions for specific criteria.] | Overall assessment

The four Working Group members who participated in the instrument testing agreed with the study team's decision to exclude additional questions that had been included in an earlier version of the item bank.29 The excluded questions concerned: the quality of the reporting in the article, such as the description of the inclusion criteria and the intervention because we retained questions that were designed to more directly measure bias; funding source because a clear relationship between source of funding and risk of bias has not been established; applicability, such as the length of followup, because this is not related to internal validity; and redundancies. Questions concerning the validity and/or reliability of various measures were combined (inclusion/exclusion, interventions, outcomes, and confounders), as were questions concerning attrition, which were also reframed as concerns about missing data.

## Assess Individual Studies for Risk of Bias and Potential Confounders

In Step D, the observational studies included in the body of evidence are reviewed to determine their risk of bias. Reviewers must also identify confounders that are controlled in specific study analyses and determine if additional confounders were identified by study authors. In an earlier version of the item bank, we developed detailed instructions to assist reviewers. During this iteration, we made minor edits to the instructions, based on comments from Working Group members, peer reviewers and team members' improvements in readability. Table 2 presents the final included questions, revised detailed instructions for each question, and the type of bias that each question is designed to uncover. Appendix C provides the instrument in detail, along with response categories. As noted above, we have eliminated from the item bank the questions designed to evaluate precision.

## Consider Competing Hypotheses for Observational Studies

In Step E, the usual culmination of the systematic review is the assessment of the strength of the body of evidence. The dominant approaches to conducting this step of the systematic review comes from the GRADE Working Group and related systems, such as the AHRQ approach to grading the strength of evidence.28 These systems aim to offer a systematic and explicit approach to making judgments about the evidence: systematic reviewers provide an assessment of their confidence about how close the true effect is to the observed effect (strong, moderate, low, very low confidence/insufficient evidence to make a determination)10 by considering study limitations, indirectness, imprecision, inconsistency, and publication/reporting bias. The body of evidence from trials generally begins with a high confidence and then is marked down for various flaws; nonrandomized/observational study bodies of evidence start with low confidence and then can be marked up if they demonstrate characteristics that would increase the reviewers' confidence in the findings from these designs such as a large magnitude of effect, dose-response relationship, or plausible confounding that would have otherwise weakened the effect estimate.38,39

These criteria (limitations of the body of evidence, indirectness, imprecision, inconsistency, and publication/reporting bias) draw from a long tradition of using causal criteria to evaluate the validity of causal links, dating back to the 1964 report of the Advisory Committee to the Surgeon General on the association between smoking and lung cancer,40 a 1965 keynote address by Bradford Hill,41 and a 1973 textbook by Susser.42 Bradford Hill presented nine causal criteria (“viewpoints”) to consider when interpreting an association as causal in nature. These included: strength (Is the strength of the association large enough that it would be difficult to explain by other factors?), consistency (Is the association observed by different persons, in different circumstances, and at different times?), specificity (Does a specific exposure lead to a specific outcome?), temporality (Does the exposure precede the outcome?), biological gradient (Does a dose-response curve exist?), plausibility (Is the association biologically plausible?), coherence (Does the observed association fit in with what is known about the natural history of the disease?), experiment (Do experiments with the exposure alter the frequency of the outcome?), and analogy (Do other examples exist that support a similar association?).41

Schünemann et al. note that the GRADE approach to assessing the quality of the evidence and strength of recommendations draws both implicitly and explicitly from numerous Bradford Hill criteria for establishing causation. They also postulate that specificity, as defined by Bradford Hill, is not an important criterion for evaluating the effects of interventions43 (because a single cause can result in multiple effects and vice versa).^b^ With regard to how concerns about threats to causality are interpreted for observational study bodies of evidence, both GRADE and the AHRQ EPC approach start observational study evidence at a lower level than trials, thus acknowledging the experimental evidence criterion; they initially downgrade designs that do not address temporality (either through randomization or through concurrent control groups). They do so overall, and make no distinction between study evaluated intended benefit and unintended harm. Strength of evidence assessments require critical consideration of confounders, factors that are more likely to plague observational studies.^c^ The primary intent of this approach is to examine whether or not a particular intervention works, or the extent to which it works. Plausible confounding is interpreted as “reverse confounding”; that is, in the absence of confounding, the effect would have been even stronger. This approach is not intended to evaluate alternative reasons for an observed phenomenon: plausible confounding, in this context, serves to raise confidence in the observational data rather than suggest another explanation for the data. Given the likelihood of multiple observed and unobserved confounders in observational data, the review of evidence on a single hypothesis is unlikely to definitively prove causality. Systematic reviews of observational studies must go beyond grading the evidence to explicitly assess competing hypotheses if they seek to understand causality.

b Others suggest that specificity does play an important role in causal inference because the construct of an effect having a single cause can be used to distinguish causal relationships from noncausal associations.44

c Schünemann et al. note that the GRADE system separates judgment about the quality of evidence from the strength of recommendations. Low or moderate quality evidence does not preclude a recommendation for or against an intervention. The implication is that observational studies can still lead to recommendations and action.43

Criticisms of meta-analyses of observational studies point to the need for critical analysis that focuses on study heterogeneity.26,45 One such criticism relates to the overinterpretation of confidence intervals that exclude the null value. Researchers point out that narrow confidence intervals could arise from spurious precision26 and represent only one type of uncertainty.45 Another criticism relates to overreliance of the consistency criterion when evaluating the strength of evidence: MacLure et al. note that the “consistency criterion corroborates the causal hypothesis of interest only indirectly by refuting confounders and biases that differ across studies. It does not refute confounders and biases that recur consistently in many studies.”45, p. 347 Thus a single study that accounts for confounding may be more believable than the pooled estimate from numerous studies that fail to account for confounding.46

Our proposed approach, illustrated in Figures 2 and 3 builds on the strength of evidence assessment to evaluate multiple competing hypotheses as a final step of the analysis. An approach such as this one shows that risks of this additional critical appraisal include incompleteness (no review can completely rule out alternative hypotheses) and complexity (multiple pathways to the outcome).45,47 Figure 2 offers an example of how confounders can be catalogued for each study and Figure 3 illustrates how the synthesis can incorporate competing hypotheses.

Figure 2 Example of systematic review listing potential confounders when evaluating the effect of cesarean delivery on maternal request on maternal and neonatal outcomes

Source: Viswanathan M, Visco AG, Hartmann K, Wechter, ME, Gartlehner G, Wu JM, Palmieri R, Funk MJ, Lux, LJ, Swinson T, Lohr KN. Cesarean Delivery on Maternal Request. Evidence Report/Technology Assessment No. 133. (Prepared by the RTI International-University of North Carolina Evidence-Based Practice Center under Contract No. 290-02-0016.) AHRQ Publication No. 06-E009. Rockville, MD: Agency for Healthcare Research and Quality. March 2006. Page 61.

Figure 2 is a table drawn from an existing report evaluating the effect of cesarean delivery on maternal request on maternal and neonatal outcomes. The table notes whether each study includes women with indication such placenta previa, repeat cesarean, and multiple gestation that serve as confounders in the relationship between the mode of delivery and the outcome.

Figure 3 Example of use of information on confounders in synthesis

Source: Viswanathan M, Visco AG, Hartmann K, Wechter, ME, Gartlehner G, Wu JM, Palmieri R, Funk MJ, Lux, LJ, Swinson T, Lohr KN. Cesarean Delivery on Maternal Request. Evidence Report/Technology Assessment No. 133. (Prepared by the RTI International-University of North Carolina Evidence-Based Practice Center under Contract No. 290-02-0016.) AHRQ Publication No. 06-E009. Rockville, MD: Agency for Healthcare Research and Quality. March 2006. Page 120-121.