# References

1 Greenland S, Morgenstern H. Confounding in health research. Annu Rev Public Health. 2001;22:189-212. [pmid: 11274518].
2 Hernán MA, Taubman SL. Does obesity shorten life? The importance of well-defined interventions to answer causal questions. Int J Obes (Lond). Aug. 2008;32(Suppl 3):S8-14. [pmid: 18695657].
3 Hernán MA, Robins JM. Casual inference. Harvard. 2012.
4 Norris SL, Atkins D. Challenges in using nonrandomized studies in systematic reviews of treatment interventions. Ann Intern Med. Jun. 21. 2005;142(12 Pt 2):1112-9. [pmid: 15968036].
5 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
6 Rothman KJ, Greenland S, Lash TL. Modern Epidemiology. 3rd ed. Philadelphia, PA. Lippincott, Williams, & Wilkins. 2008.
7 Norris SL, Atkins D, Bruening W, et al. Observational studies in systemic reviews of comparative effectiveness: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1178-86. [pmid: 21636246].
8 Eden J, Levit L, Berg A, et al., editors. Finding What Works in Health Care: Standards for Systematic Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
9 Reeves BC, Deeks JJ, Higgins JPT, et al. Chapter 13: Including non-randomized studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration. 2011.
10 Balshem H, Helfand M, Schünemann HJ, et al. GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. Apr. 2011;64(4):401-6. [pmid: 21208779].
11 Hernán MA, Hernández-Díaz S, Robins JM. A structural approach to selection bias. Epidemiology. Sep. 2004;15(5):615-25. [pmid: 15308962].
12 Etminan M, Sadatsafavi M, Jafari S, et al. Acetaminophen use and the risk of asthma in children and adults: a systematic review and metaanalysis. Chest. Nov. 2009;136(5):1316-23. [pmid: 19696122].
13 Lowe AJ, Carlin JB, Bennett CM, et al. Paracetamol use in early life and asthma: prospective birth cohort study. Br Med J. Sep. 15. 2010;341:c4616. [pmid: 20843914].
14 Vandenbroucke JP. Why do the results of randomised and observational studies differ?. BMJ. 2011;343:d7020. [pmid: 22065658].
15 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. Jun. 22. 2000;342(25):1887-92. [pmid: 10861325].
16 MacLehose RR, Reeves BC, Harvey IM, et al. A systematic review of comparisons of effect sizes derived from randomised and non-randomised studies. Health Technol Assess. 2000;4(34):1-154. [pmid: 11134917].
17 Ioannidis JP, Haidich AB, Pappa M, et al. Comparison of evidence of treatment effects in randomized and nonrandomized studies. JAMA. Aug. 15. 2001;286(7):821-30. [pmid: 11497536].
18 Odgaard-Jensen J, Vist GE, Timmer A, et al. Randomisation to protect against selection bias in healthcare trials. Cochrane Database Syst Rev. 2011;(4):MR000012. [pmid: 21491415].
19 Shrier I, Boivin JF, Steele RJ, et al. Should meta-analyses of interventions include observational studies in addition to randomized controlled trials? A critical examination of underlying principles. Am J Epidemiol. Nov. 15. 2007;166(10):1203-9. [pmid: 17712019].
20 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
21 Mhaskar R, Djulbegovic B, Magazin A, et al. Published methodological quality of randomized controlled trials does not reflect the actual quality assessed in protocols. J Clin Epidemiol. Jun. 2012;65(6):602-9. [pmid: 22424985].
22 von Elm E, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. J Clin Epidemiol. Apr. 2008;61(4):344-9. [pmid: 18313558].
23 Juni P, Altman DG, Egger M. Systematic reviews in health care: assessing the quality of controlled clinical trials. BMJ. Jul. 7. 2001;323(7303):42-6. [pmid: 11440947].
24 Colliver JA, Kucera K, Verhulst SJ. Meta-analysis of quasi-experimental research: are systematic narrative reviews indicated?. Med Educ. Sep. 2008;42(9):858-65. [pmid: 18715482].
25 Blair A, Burg J, Foran J, et al. Guidelines for application of meta-analysis in environmental epidemiology. ISLI Risk Science Institute. Regul Toxicol Pharmacol. Oct. 1995;22(2):189-97. [pmid: 8577954].
26 Egger M, Schneider M, Davey Smith G. Spurious precision? Meta-analysis of observational studies. BMJ. Jan. 10. 1998;316(7125):140-4. [pmid: 9462324].
27 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. March. 2012. www.effectivehealthcare.ahrq.gov/ehc/products/322/998/MethodsGuideforCERs_Viswanathan_IndividualStudies.pdf.
28 Owens DK, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions. Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
29 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. [pmid: 21959223].
30 Hartling L, Bond K, Santaguida PL, et al. Testing a tool for the classification of study designs in systematic reviews of interventions and exposures showed moderate reliability and low accuracy. J Clin Epidemiol. Aug. 2011;64(8):861-71. [pmid: 21531537].
31 Hartling L, Bond K, Harvey K, et al. Developing and Testing a Tool for the Classification of Study Designs in Systematic Reviews of Interventions and Exposures. Methods Research Report. (Prepared by University of Alberta Evidence-based Practice Center under Contract No. 290-002-0023). AHRQ Publication No. 11-EHC007-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
32 Helfand M. AHRQ series editorial: public involvement improves methods development in comparative effectiveness reviews. J Clin Epidemiol. May. 2010;63(5):471-3. [pmid: 20346860].
33 Helfand M, Balshem H. AHRQ series paper 2: principles for developing guidance: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):484-90. [pmid: 19716268].
34 Slutsky J, Atkins D, Chang S, et al. AHRQ series paper 1: comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):481-3. [pmid: 18834715].
35 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
36 Shrier I. Structural Approach to Bias in Meta-analyses. Research Synthesis Methods. 2011;2(4):223-37.
37 Guyatt GH, Oxman AD, Kunz R, et al. GRADE guidelines: 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. Dec. 2011;64(12):1283-93. [pmid: 21839614].
38 Guyatt GH, Oxman AD, Sultan S, et al. GRADE guidelines: 9. Rating up the quality of evidence. J Clin Epidemiol. Dec. 2011;64(12):1311-6. [pmid: 21802902].
39 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol. Apr. 2011;64(4):383-94. [pmid: 21195583].
40 United States. Surgeon General's Advisory Committee on Smoking and Health. Smoking and health report of the advisory committee to the Surgeon General of the Public Health Service. Public Health Service publication no 1103. Washington, D.C. U.S. Dept. of Health, Education, and Welfare, Public Health Service. 1964:xvii. 387 p. ill. 24 cm.
41 Hill AB. The Environment and Disease: Association or Causation?. Proc R Soc Med. May. 1965;58:295-300. [pmid: 14283879].
42 Susser M, Andjelkovich D. Causal thinking in the health sciences; concepts and strategies of epidemiology. New York. Oxford University Press. 1973.
43 Schünemann H, Hill S, Guyatt G, et al. The GRADE approach and Bradford Hill's criteria for causation. J Epidemiol Community Health. May. 2011;65(5):392-5. [pmid: 20947872].
44 Weiss NS. Can the "specificity" of an association be rehabilitated as a basis for supporting a causal hypothesis?. Epidemiology. Jan. 2002;13(1):6-8. [pmid: 11805580].
45 Maclure M. Demonstration of deductive meta-analysis: ethanol intake and risk of myocardial infarction. Epidemiol Rev. 1993;15(2):328-51. [pmid: 8174661].
46 Vandenbroucke JP. Statins and infections: sloppy causal thinking in meta-analyses of observational research. BMJ. 2012. 1. February.
47 Cornfield J, Haenszel W, Hammond EC, et al. Smoking and lung cancer: recent evidence and a discussion of some questions. J Natl Cancer Inst. Jan. 1959;22(1):173-203. [pmid: 13621204].