# Peer Reviewers

- Ethan M. Balk, M.D., M.P.H.
  Tufts Medical Center
  Boston, MA
- Donna Ciliska, R.N., Ph.D.
  McMaster University Faculty of Health Sciences
  Hamilton, Ontario, Canada
- Kathleen Gans-Brangs
  AstraZeneca Canada, Inc.
  Wilmington, DE
- Ian Shrier, M.D., Ph.D.
  McGill University
  Montreal, Quebec, Canada
- James Restom, Ph.D.
  ECRI Institute Evidence-based Practice Center
  Plymouth Meeting, PA
- Karen Robinson, Ph.D.
  Johns Hopkins Evidence based Practice Center
  Baltimore, MD
- Barbara Mauger Rothenberg, Ph.D.
  Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center
  Chicago, IL
- Alric Rüther, M.D.
  Institute for Quality and Efficiency in Health Care
  Cologne, Germany
- Holger Schünemann, M.D., M.Sc., Ph.D.
  McMaster University
  Hamilton, Ontario, Canada