# Workgroup Members

- Mohammed T. Ansari, M.B.B.S., M.Med.Sc., M.Phil.
  University of Ottawa Evidence-based Practice Center
  Ottawa, Canada
- Nancy Dreyer, M.P.H., Ph.D.
  Outcome Sciences Inc.
  Cambridge, MA
- Susan Norris, M.D., M.Sc., M.P.H.
  Oregon Health and Science University
  Portland, OR,
- Ida Sim, Ph.D., M.D.
  University of California San Francisco School of Medicine
  San Francisco, CA
- Tatyana Shamliyan, M.D.
  University of Minnesota Evidence-based Practice Center
  Minneapolis, MN
- Jan Vandenbroucke, M.D., Ph.D.
  Dept. of Clinical Epidemiology, Leiden University Hospital
  Leiden, Netherlands