# Acknowledgments

We gratefully acknowledge the contributions of the associate editor, Mark Helfand, M.D., M.S., M.P.H, the EPC editor, Jennifer Drolet, M.A., Sharon Barrell, M.A., research assistant, Priyanka Sista, B.A., and the EPC publications specialist, Loraine Monroe.