# Approaches to Assessing the Risk of Bias in Studies

Approaches to critical appraisal of study methodology and related terminology has varied and is evolving. Overlapping terms include quality, internal validity, risk of bias, or study limitations, but a central goal is an assessment of the validity of the findings. We use the phrase “assessment of risk of bias” as the most representative of the goal of evaluating the degree to which the effects reported by a study represent the “true” causal relationship between exposure and outcome.

A valid estimate requires the absence of bias or systematic error in selection, performance, detection, measurement, attrition, and reporting and adequacy in addressing potential confounding. The interpretation of the effect of an estimate also requires the evaluation of precision (the absence of random error through adequate study size and study efficiency).1 For studies that do not lend themselves to quantitative pooling of estimates, reviewers will likely be making assessments of individual study risk of bias and precision at the same time, supporting the broader notion of evaluating study quality. Thorough assessment of these threats to the validity of an estimate is critical to understanding the believability and interpretation of a study.

Table 1 builds on and revises, drawing on numerous sources,1-3 the Cochrane Collaboration taxonomy4 of threats to validity and precision to expand the discussion of confounding and selection bias.

Table 1 Threats to validity and precision^a^

Threats | Definition
Threats to validity (systematic error)
Confounding by indication or allocation bias | Systematic differences between baseline characteristics of the groups that arise when patient prognostic characteristics, such as disease severity or comorbidity, influence both treatment source and outcomes. Confounders are the common cause for intervention and exposure; they occur before exposure. Confounding by indication can occur from self-selection of treatments or physician-directed selection of treatments.
Selection bias | Selection bias occurs when studies are conditioned on (that is, they differentially select for) common effects of the exposure and the outcome. Selection bias occurs after exposure and arises when the association between exposure and outcome is different for those who participate compared with those who do not participate in a study (i.e., all those who are theoretically eligible). Includes inappropriate selection of controls in a case-control study, differential loss to follow-up for groups being compared (attrition bias), incidence-prevalence bias, nonresponse bias, and in- or exclusion of specific groups for study.
Performance bias | Systematic differences in the care provided to participants and protocol deviation. Examples include contamination of the control group with the exposure or intervention, unbalanced provision of additional interventions or co-interventions, difference in co-interventions, and inadequate blinding of providers and participants.
Detection bias | Systematic differences in outcomes assessment among groups being compared, including misclassification of the exposure or intervention, covariates, or outcomes because of variable definitions and timings, diagnostic thresholds, recall from memory, inadequate assessor blinding, and faulty measurement techniques. Erroneous statistical analysis might also affect the validity of effect estimates.
Reporting bias | Systematic differences between reported and unreported findings (e.g., differential reporting of outcomes or harms, incomplete reporting of study findings, potential for bias in reporting through source of funding).
Threats to precision (random error)
Inadequate study size | Not powered to test study hypothesis for an individual study. (Multiple underpowered small studies can result in a precise meta-analysis estimate)
Lack of study efficiency | Absence of needed stratification in design. When confounding and effect modifiers do not exist, an equal apportionment ratio between exposed and unexposed is the most efficient design. Comparisons within strata may be required to account for known confounders and effect modifiers. Matching on stratification variables allows for an efficient design.

a From Hernan et al., 2004,^2^ Rothman et al., 2003,^1^ Higgins et al., 2006,^4^ and Viswanathan et al., 2012.^3^

The inclusion of observational studies considerably expands the challenges in establishing causal inference in systematic reviews. Observational studies cannot, by design, offer establish causality through features such as randomization and concealment of allocation. They are therefore at greater risk than RCTs for confounding by indication and selection bias.

In contrast, threats to validity and precision from performance bias, detection bias, inadequate sample size, and lack of study efficiency do not differ markedly in theory between RCTs and observational studies (although some features such as blinding of assessors that protect against detection bias are more likely in experimental designs than in observational studies). For both designs, these risks of bias can threaten the validity of results. Performance bias and detection of effects have the potential to alter effect sizes unpredictably and need to be evaluated as well in observational studies.4,5 These sources of bias can invalidate the results of observational studies, as can problems with confounding and selection bias. In relation to risks from confounding, Greenland and Morgenstern note that “[b]iases of comparable or even greater magnitude can arise from measurement errors, selection (sampling) biases, and systematically missing data, as well as from model-specification errors. Even when confounding and other systematic errors are absent, individual causal effects will remain unidentified by statistical observations.”6, ^p. 208^

## Confounding

Although confounding is more of a concern for observational studies than RCTs, RCTs are not entirely free of these concerns. Confounding that is random (by chance) is expected to be equally distributed between arms by randomization, but RCTs may not always successfully randomize such potential confounders. Confounding by chance (that is confounding that is unknown, unmeasured, or poorly measured, but expected to be equally distributed) should occur with the same probability in RCTs and observational studies, because, it is, by definition, occurring by chance.7 Confounding by indication or contraindication, on the other hand, occurs when both treatment and outcome are influenced by a third factor, namely prognosis. Confounding by indication can occur when the expectation of prognosis influences the patient or provider's selection of treatment as well as the potential outcome. Trials, by virtue of concealed randomization, avoid this source of confounding, by “breaking the link between prognosis and prescription.”8, ^p. e67^ Observational studies of benefits that cannot address source of confounding by design (through, for instance, restriction to patients with the same prognosis) must account for it in analysis to the extent possible. Vandenbroucke notes that confounding by contraindication is not always a concern for observational studies of harms: harms are often unanticipated outcomes, so an expectation of prognosis for harms is unlikely to have influenced the selection of treatment.8, ^p. e67^ The extent to which confounding by indication may occur in observational studies of harms lies on a gradient, from the completely unanticipated (as with ACE inhibitors and angioneurotic edema) to the potentially likely (as with cardiac arrhythmias induced by anti-arrhythmic drugs).

Confounding by indication may also occur when the person allocating treatment is influenced by factors other than prognosis. Shrier et al. offer the example of the appearance of fatigue causing the physician to select one diabetes treatment over another.7 When confounding by indication can be controlled, for instance, by the inclusion of physician-rated appearance of patient fatigue as a covariate in modeling, the effect of the potential confounder can be accounted for. Each analysis need only account for those confounders that are expected to have an effect on the outcome and that have not already been accounted for by the inclusion of other closely correlated variables. Thus, the assessment of the potential for bias from confounding requires context-specific understanding of the relationship between treatment and outcomes and study-specific evaluation.1,6,7

## Selection Bias

Selection bias refers to the selection of the subset of those eligible, when that selection is conditioned upon variables that are the common effect of causes of the exposures and outcomes.1,2 The specific risks of selection bias vary by type of observational study design. Differential loss to follow-up, for instance, is a concern for cohort studies but not for case-series or cross-sectional studies. On the other hand, a choice of control group that is intrinsically either more or less exposed than the source population of the cases, is a specific form of selection bias in case-control studies.

The concerns regarding attrition bias, however, are similar for RCTs and observational studies in theory: both types of studies may be weakened by high rates of overall or differential attrition. In practice, observational studies may have higher risks of attrition bias: they may have longer time horizons and fewer resources to follow up with participants

Lastly, RCTs often suffer less from inadvertent selection bias caused by the analysis. Usually, in RCTs, investigators will not adjust for other consequences of the treatment, nor will they adjust for consequences of the outcome. However, in large data-base analysis, that is sometimes done unwittingly, as with restriction of the analysis on folic acid supplementation on congenital malformation to live births.2

## Performance Bias

The risk of performance bias may differ in practice between RCTs and observational studies. In a RCT the intervention is typically standardized so that study participants within groups are exposed (for the most part) to similar interventions or control conditions. Further, co-interventions can be standardized and/or monitored and fidelity to the intervention can be assessed and reported. For observational studies, this standardization may not be possible; therefore, researchers may not have control over how the intervention was administered or the level of exposure. As a result, observational studies may not be able to clearly define intervention states. Hernan and Taubman note that when the principle of consistency (a causal contrast between two or more well defined interventions) is not met (as with studies exploring whether obesity leads to increased mortality), other requirements of caual inference such as exchangeability and positivity cannot be met.9 This will also vary by specific observational study design features, particularly whether the intervention/exposure occurred prospectively vs. retrospectively with respect to the conduct of the study. Blinding of the providers and participants may also be of variable concern across different designs. For instance, in a retrospective study, the intervention or exposure would likely have been administered outside the context of a research study; therefore, blinding of the intervention/exposure may not be applicable. In a prospective study, by contrast, blinding of providers and participants is critical to limiting bias that arises as a result of knowing the study hypothesis and what the study participants are receiving. Blinding, or other measures that make assessments objective, is possible in assessing the exposure status of individuals in case-control studies.

## Detection Bias

As with performance bias, detection bias may be more problematic in observational studies because outcome assessment may not be standardized as it is more typically with RCTs. For example, in RCTs the same outcome assessment tools are used often with protocols for their implementation and assessment of results. As above, this source of bias can also vary across observational studies, particularly for prospective vs. retrospective designs. In retrospective designs where the measurement of outcomes has occurred prior to the start of the study, the researchers have no control over how those assessments were made, including choice of measurement tools, whether tools were valid and reliable (or a process to ensure their validity/reliability was employed), and how results were interpreted. Blinding of outcome assessors serves to limit detection bias, but not all designs can employ a blinded approach to assessing outcomes. In some studies, researchers serve as outcome assessors and can be blinded; in other studies, participants provide self-reported outcome data and cannot be blinded. As above, blinding of outcome assessors may be of variable concern across different observational study designs.

Information bias is related to detection bias and arises from how measurement and assessment of exposure and outcomes are made. In theory, all designs run the risk of bias from the use of poorly validated measures.

## Reporting Bias

Reporting bias is a concern across all research regardless of design: authors are more likely to publish studies and selectively report outcomes that show statistical significance. However, with the recent emphasis on standardized reporting of RCTs and prospective trial registration, reporting bias may become less problematic with RCTs or at least more easily detected as a problem in specific RCTs. While no empirical evidence exists that reporting bias is a greater concern for observational studies, fewer standards exist for observational studies, making reporting bias a concern of equal or greater magnitude than for RCTs.

## References

1 Rothman KJ, Greenland S, Lash TL. Modern Epidemiology. 3rd ed. Philadelphia, PA. Lippincott, Williams, & Wilkins. 2008.
2 Hernán MA, Hernández-Díaz S, Robins JM. A structural approach to selection bias. Epidemiology. Sep. 2004;15(5):615-25. [pmid: 15308962].
3 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. [pmid: 21959223].
4 Higgins JPT, Green S. Cochrane handbook for systematic reviews of interventions version 5.0.2. London. The Cochrane Collaboration. 2009. www.cochrane-handbook.org. June 9, 2011.
5 Juni P, Altman DG, Egger M. Systematic reviews in health care: Assessing the quality of controlled clinical trials. BMJ. Jul. 7. 2001;323(7303):42-6. [pmid: 11440947].
6 Greenland S, Morgenstern H. Confounding in health research. Annu Rev Public Health. 2001;22:189-212. [pmid: 11274518].
7 Shrier I, Boivin JF, Steele RJ, et al. Should meta-analyses of interventions include observational studies in addition to randomized controlled trials? A critical examination of underlying principles. Am J Epidemiol. Nov. 15. 2007;166(10):1203-9. [pmid: 17712019].
8 Vandenbroucke JP. Observational research, randomised trials, and two views of medical science. PLoS Med. Mar. 11. 2008;5(3):e67. [pmid: 18336067].
9 Hernán MA, Taubman SL. Does obesity shorten life? The importance of well-defined interventions to answer causal questions. Int J Obes (Lond). Aug. Suppl 3. 2008;32:S8-14. [pmid: 18695657].