# References

1 Basu A. Economics of individualization in comparative effectiveness research and a basis for a patient-centered health care. J Health Econ. May. 2011;30(3):549-59. Epub April 23, 2011. [pmid: 21601299].
2 Committee on Comparative Effectiveness Research Prioritization IoM. Initial National Priorities for Comparative Effectiveness Research. June. 30. 2009. www.nap.edu/catalog/12648.html.
3 Institution B. Implementing comparative effectiveness research: Priorities, methods, and impact. The Hamilton Project. June. 2009:1-88.
4 Coory M, Jordan S. Frequency of treatment-effect modification affecting indirect comparisons: a systematic review. Pharmcoeconomics. 2010;28(9):723-32.
5 Wells G, Sultan S, Chen L, et al. Indirect evidence: Indirect treatment comparisons in meta-analysis. Canadian Agency for Drugs and Technologies in Health. 2009. Ottawa.
6 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. Jul. 2005;9(26):1-134. iii. iv. [pmid: 16014203].
7 Song F, Loke YK, Walsh T, et al. Methodological problems in the use of indirect comparisons for evaluating healthcare interventions: survey of published systematic reviews. BMJ. 2009;338:b1147. [pmid: 19346285].
8 Donegan S, Williamson P, Gamble C, et al. Indirect comparisons: a review of reporting and methodological quality. PLoS One. 2010;5(11):e11054. [pmid: 21085712].
9 Jansen JP, Fleurence R, Devine B, et al. Interpreting indirect treatment comparisons and network meta-analysis for health-care decision making: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 1. Value Health. Jun. 2011;14(4):417-28. [pmid: 21669366].
10 Hoaglin DC, Hawkins N, Jansen JP, et al. Conducting indirect-treatment-comparison and network-meta-analysis studies: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 2. Value Health. Jun. 2011;14(4):429-37. [pmid: 21669367].
11 Dias S, Welton NJ, Caldwell DM, et al. Checking consistency in mixed treatment comparison meta-analysis. Stat Med. Mar. 30. 2010;29(7-8):932-44. [pmid: 20213715].
12 Dias S, W NJ, Sutton AJ, Caldwell DM, Lu C, Ades AE. Inconsistency in Networks of evidence based on randomized controlled trials. NICE DSU TECHNICAL SUPPORT. 2011;4(May):1-39.
13 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. Aug. 30. 2002;21(16):2313-24. [pmid: 12210616].
14 Shamliyan T, Wyman J, Kane RL. Nonsurgical Treatments for Urinary Incontinence in Adult Women: Diagnosis and Comparative Effectiveness. AHRQ Publication No. 11-EHC074. Rockville, MD. Agency for Healthcare Research and Quality. 2001;36. Prepared by the University of Minnesota Evidence-based Practice Center under Contract No. HHSA 290-2007-10064-I.
15 Haylen BT, de Ridder D, Freeman RM, et al. An International Urogynecological Association (IUGA)/International Continence Society (ICS) joint report on the terminology for female pelvic floor dysfunction. Neurourol Urodyn. 2010;29(1):4-20. [pmid: 19941278].
16 Abrams P. Incontinence: 4th International Consultation on Incontinence. Paris. July 5-8, 2008. Health Publications Ltd. 2009. Committee 12. Adult Conservative Management.
17 U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health, et al. Draft Guidance for Industry and FDA Staff - Clinical Investigations of Devices Indicated for the Treatment of Urinary Incontinence. Rockville, MD. 20852. Food and Drug Administration. 2008. www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm070852.htm. August 2009.
18 Coyne KS, Sexton CC, Kopp ZS, et al. The impact of overactive bladder on mental health, work productivity and health-related quality of life in the UK and Sweden: results from EpiLUTS. BJU Int. 2011. Mar. 3. [pmid: 21371240].
19 Berry SM, Ishak KJ, Luce BR, et al. Bayesian meta-analyses for comparative effectiveness and informing coverage decisions. Med Care. Jun. 2010;48(6 Suppl):S137-44. [pmid: 20473185].
20 O'Regan C, Ghement I, Eyawo O, et al. Incorporating multiple interventions in meta-analysis: an evaluation of the mixed treatment comparison with the adjusted indirect comparison. Trials. 2009;10:86. [pmid: 19772573].
21 Abrams P. Incontinence: 4th International Consultation on Incontinence. Paris. July 5-8, 2008. 4th ed. [Paris]. Health Publications Ltd. 2009.
22 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
23 Smith TC, Speigelhalter DJ, Thomas SL. Bayesian approaches to random-effects meta-analysis: a comparative study. Statistics in Medicine. 1995;14:2685-99. [pmid: 8619108].
24 Nixon RM, Bansback N, Brennan A. Using mixed treatment comparisons and meta-regression to perform indirect comparisons to estimate the efficacy of biologic treatments in rheumatoid arthritis. Statistics in Medicine. 2007;26:1237-54. [pmid: 16900557].
25 Lu G, Ades A. Assessing evidence inconsistency in Mixed Treatment Comparisons. Journal of the American Statistical Association. 2006;101:447-59.
26 Lu G, Ades A. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
27 Carlin B, Louis T. Bayesian Methods for Data Analysis. 3rd edition. Boca Raton, FL. Chapman and Hall/CRC Press. 2009:71.
28 Spiegelhalter D, Best N, Carlin B, et al. Bayesian Measures of Model Complexity and Fit (with Discussion). J Roy Statist Soc. Ser B. 2002;64:583-639.
29 White IR. Multivariate random-effects meta-regression: Updates to mvmeta. The Stata Journal. 2011;11(12).
30 Jones B, Roger J, Lane PW, et al. Statistical approaches for conducting network meta-analysis in drug development. Pharm Stat. Nov-Dec. 2011;10(6):523-31. [pmid: 22213533].
31 StataCorp. Stata Statistical Software. Release 12. 2011. College Station, TX (StataCorp LP).
32 Altman DG. Confidence intervals for the number needed to treat. Bmj. Nov. 7. 1998;317(7168):1309-12. [pmid: 9804726].
33 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London. NetLibrary, Inc. BMJ Books. 2001.
34 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
35 Lunn D, Thomas A, Best N, et al. WinBUGS- a Bayesian modelling framework: concepts, structure, and extensibility. Statistics and Computing. 2000;10:325-37.
36 SAS Institute Inc. C, NC, USA. SAS 9.2. Copyright © 2009. 2012.
37 Cipriani A, Barbui C, Salanti G, et al. Comparative efficacy and acceptability of antimanic drugs in acute mania: a multiple-treatments meta-analysis. Lancet. Oct. 8. 2011;378(9799):1306-15. [pmid: 21851976].
38 Kaplan SA, Schneider T, Foote J, et al. Superior efficacy of fesoterodine over tolterodine with rapid onset: A prospective, head-to-head, placebo-controlled trial. Neurourology and Urodynamics. 2010;29:905-7.
39 NCT00444925. Clinical Trial to Evaluate the Efficacy and Safety of Fesoterodine in Comparison to Tolterodine for Overactive Bladder (OAB). www.clinicaltrials.gov/ct2/show/NCT00444925?term=NCT00444925&rank=1.
40 Junemann KP, Hessdorfer E, Unamba-Oparah I, et al. Propiverine hydrochloride immediate and extended release: comparison of efficacy and tolerability in patients with overactive bladder. Urol Int. 2006;77(4):334-9. [pmid: 17135784].
41 Zinner N, Gittelman M, Harris R, et al. Trospium chloride improves overactive bladder symptoms: a multicenter phase III trial. J Urol. Jun. 2004;171(6 Pt 1):2311-5. quiz 435. [pmid: 15126811].
42 Goode PS. Behavioral and drug therapy for urinary incontinence. Urology. Mar. 2004;63(3 Suppl 1):58-64. [pmid: 15013654].
43 Moore KH, Hay DM, Imrie AE, et al. Oxybutynin hydrochloride (3 mg) in the treatment of women with idiopathic detrusor instability. Br J Urol. Nov. 1990;66(5):479-85. [pmid: 2249115].
44 Dorschner W, Stolzenburg JU, Griebenow R, et al. Efficacy and cardiac safety of propiverine in elderly patients - a double-blind, placebo-controlled clinical study. Eur Urol. Jun. 2000;37(6):702-8. [pmid: 10828671].
45 Vardy MD, Mitcheson HD, Samuels TA, et al. Effects of solifenacin on overactive bladder symptoms, symptom bother and other patient-reported outcomes: results from VIBRANT - a double-blind, placebo-controlled trial. Int J Clin Pract. Dec. 2009;63(12):1702-14. [pmid: 19930331].
46 Staskin DR, Dmochowski RR, Sand PK, et al. Efficacy and safety of oxybutynin chloride topical gel for overactive bladder: a randomized, double-blind, placebo controlled, multicenter study. J Urol. Apr. 2009;181(4):1764-72. [pmid: 19233423].
47 Chu F, Smith N, Uchida T. Efficacy and safety of solifenacin succinate 10 mg once Daily: A multicenter, phase III, randomized, double-blind, placebo-controlled, parallel-group trial in patients with overactive bladder. Current Therapeutic Research. December. 2009;70(6):405-20.
48 Cardozo L, Castro-Diaz D, Gittelman M, et al. Reductions in overactive bladder-related incontinence from pooled analysis of phase III trials evaluating treatment with solifenacin. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):512-9. [pmid: 16625311].
49 Staskin DR, Te AE. Short- and long-term efficacy of solifenacin treatment in patients with symptoms of mixed urinary incontinence. BJU Int. Jun. 2006;97(6):1256-61. [pmid: 16686722].
50 Karram MM, Toglia MR, Serels SR, et al. Treatment with solifenacin increases warning time and improves symptoms of overactive bladder: results from VENUS, a randomized, double-blind, placebo-controlled trial. Urology. Jan. 2009;73(1):14-8. [pmid: 18995887].
51 Sand PK, Dmochowski RR, Zinner NR, et al. Trospium chloride extended release is effective and well tolerated in women with overactive bladder syndrome. Int Urogynecol J Pelvic Floor Dysfunct. 2009. Aug. 29. [pmid: 19727537].
52 Staskin D, Sand P, Zinner N, et al. Once daily trospium chloride is effective and well tolerated for the treatment of overactive bladder: results from a multicenter phase III trial. J Urol. Sep. 2007;178(3 Pt 1):978-83. discussion 83-4. [pmid: 17632131].
53 Herschorn S, Swift S, Guan Z, et al. Comparison of fesoterodine and tolterodine extended release for the treatment of overactive bladder: a head-to-head placebo-controlled trial. BJU Int. Jan. 2010;105(1):58-66. [pmid: 20132103].
54 Homma Y, Paick JS, Lee JG, et al. Clinical efficacy and tolerability of extended-release tolterodine and immediate-release oxybutynin in Japanese and Korean patients with an overactive bladder: a randomized, placebo-controlled trial. BJU Int. Nov. 2003;92(7):741-7. [pmid: 14616458].
55 Abrams P, Freeman R, Anderstrom C, et al. Tolterodine, a new antimuscarinic agent: as effective but better tolerated than oxybutynin in patients with an overactive bladder. Br J Urol. Jun. 1998;81(6):801-10. [pmid: 9666761].
56 Steers W, Corcos J, Foote J, et al. An investigation of dose titration with darifenacin, an M3-selective receptor antagonist. BJU Int. Mar. 2005;95(4):580-6. [pmid: 15705084].
57 Hill S, Khullar V, Wyndaele JJ, et al. Dose response with darifenacin, a novel once-daily M3 selective receptor antagonist for the treatment of overactive bladder: results of a fixed dose study. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):239-47. [pmid: 15999217].
58 Chapple C, DuBeau C, Ebinger U, et al. Darifenacin treatment of patients >or= 65 years with overactive bladder: results of a randomized, controlled, 12-week trial. Curr Med Res Opin. Oct. 2007;23(10):2347-58. [pmid: 17706004].
59 Dmochowski RR, Peters KM, Morrow JD, et al. Randomized, double-blind, placebo-controlled trial of flexible-dose fesoterodine in subjects with overactive bladder. Urology. Jan. 2010;75(1):62-8. [pmid: 19931895].
60 Thuroff JW, Bunke B, Ebner A, et al. Randomized, double-blind, multicenter trial on treatment of frequency, urgency and incontinence related to detrusor hyperactivity: oxybutynin versus propantheline versus placebo. J Urol. Apr. 1991;145(4):813-6. discussion 6-7. [pmid: 2005707].
61 Herschorn S, Heesakkers J, Castro-Diaz D, et al. Effects of tolterodine extended release on patient perception of bladder condition and overactive bladder symptoms*. Curr Med Res Opin. Dec. 2008;24(12):3513-21. [pmid: 19032133].
62 Lee JG, Hong JY, Choo MS, et al. Tolterodine: as effective but better tolerated than oxybutynin in Asian patients with symptoms of overactive bladder. Int J Urol. May. 2002;9(5):247-52. [pmid: 12060436].
63 Lehtoranta K, Tainio H, Lukkari-Lax E, et al. Pharmacokinetics, efficacy, and safety of intravesical formulation of oxybutynin in patients with detrusor overactivity. Scand J Urol Nephrol. Feb. 2002;36(1):18-24. [pmid: 12002352].
64 Rogers R, Bachmann G, Jumadilova Z, et al. Efficacy of tolterodine on overactive bladder symptoms and sexual and emotional quality of life in sexually active women. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1551-7. [pmid: 18685795].
65 Malone-Lee JG, Al-Buheissi S. Does urodynamic verification of overactive bladder determine treatment success? Results from a randomized placebo-controlled study. BJU Int. Apr. 2009;103(7):931-7. [pmid: 19281469].
66 Dmochowski RR, Sand PK, Zinner NR, et al. Trospium 60 mg once daily (QD) for overactive bladder syndrome: results from a placebo-controlled interventional study. Urology. Mar. 2008;71(3):449-54. [pmid: 18342185].
67 Sand PK, Morrow JD, Bavendam T, et al. Efficacy and tolerability of fesoterodine in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2009;20(7):827-35. [pmid: 19495545].
68 Madersbacher H, Halaska M, Voigt R, et al. A placebo-controlled, multicentre study comparing the tolerability and efficacy of propiverine and oxybutynin in patients with urgency and urge incontinence. BJU Int. Oct. 1999;84(6):646-51. [pmid: 10510109].
69 Johnson TM 2nd, Burgio KL, Redden DT, et al. Effects of behavioral and drug therapy on nocturia in older incontinent women. J Am Geriatr Soc. May. 2005;53(5):846-50. [pmid: 15877562].
70 Wang AC, Chih SY, Chen MC. Comparison of electric stimulation and oxybutynin chloride in management of overactive bladder with special reference to urinary urgency: a randomized placebo-controlled trial. Urology. Nov. 2006;68(5):999-1004. [pmid: 17113893].
71 Szonyi G, Collas DM, Ding YY, et al. Oxybutynin with bladder retraining for detrusor instability in elderly people: a randomized controlled trial. Age Ageing. 1995/07/01 ed. 1995:287-91. [pmid: 7484484].
72 Lee KS, Lee HW, Choo MS, et al. Urinary urgency outcomes after propiverine treatment for an overactive bladder: the ‘Propiverine study on overactive bladder including urgency data’. BJU Int. Jun. 2010;105(11):1565-70. [pmid: 19912183].
73 Toglia MR, Serels SR, Laramee C, et al. Solifenacin for overactive bladder: patient-reported outcomes from a large placebo-controlled trial. Postgrad Med. Sep. 2009;121(5):151-8. [pmid: 19820284].
74 Kelleher CJ, Reese PR, Pleil AM, et al. Health-related quality of life of patients receiving extended-release tolterodine for overactive bladder. The American journal of managed care. 2002:S608-15. [pmid: 12516955].
75 Rogers RG, Bachmann G, Scarpero H, et al. Effects of tolterodine ER on patient-reported outcomes in sexually active women with overactive bladder and urgency urinary incontinence. Curr Med Res Opin. Sep. 2009;25(9):2159-65. [pmid: 19601704].
76 Staskin DR, Harnett MD. Effect of trospium chloride on somnolence and sleepiness in patients with overactive bladder. Curr Urol Rep. Dec. 2004;5(6):423-6. [pmid: 15541209].
77 Zinner N, Tuttle J, Marks L. Efficacy and tolerability of darifenacin, a muscarinic M3 selective receptor antagonist (M3 SRA), compared with oxybutynin in the treatment of patients with overactive bladder. World J Urol. Sep. 2005;23(4):248-52. [pmid: 16096831].
78 Chapple C, Van Kerrebroeck P, Tubaro A, et al. Clinical efficacy, safety, and tolerability of once-daily fesoterodine in subjects with overactive bladder. Eur Urol. Oct. 2007;52(4):1204-12. [pmid: 17651893].
79 Drutz HP, Appell RA, Gleason D, et al. Clinical efficacy and safety of tolterodine compared to oxybutynin and placebo in patients with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):283-9. [pmid: 10543335].
80 Yamaguchi O, Marui E, Kakizaki H, et al. Randomized, double-blind, placebo- and propiverine-controlled trial of the once-daily antimuscarinic agent solifenacin in Japanese patients with overactive bladder. BJU Int. Sep. 2007;100(3):579-87. [pmid: 17669143].
81 Chapple CR, Rechberger T, Al-Shukri S, et al. Randomized, double-blind placebo- and tolterodine-controlled trial of the once-daily antimuscarinic agent solifenacin in patients with symptomatic overactive bladder. BJU Int. Feb. 2004;93(3):303-10. [pmid: 14764127].
82 Chapple CR. Darifenacin: a novel M3 muscarinic selective receptor antagonist for the treatment of overactive bladder. Expert Opin Investig Drugs. Nov. 2004;13(11):1493-500. [pmid: 15500396].
83 Zinner N, Susset J, Gittelman M, et al. Efficacy, tolerability and safety of darifenacin, an M(3) selective receptor antagonist: an investigation of warning time in patients with OAB. Int J Clin Pract. Jan. 2006;60(1):119-26. [pmid: 16409440].
84 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Medical Review for Enablex (Clarifenacin) Extended Release Tablets. 2004. www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. June 25 2010.
85 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review for Enablex (Darifenacin Hydrobromide) Extended Release Tablets. 2004. www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. June 25 2010.
86 Chapple C. Fesoterodine a new effective and well-tolerated antimuscarinic for the treatment of urgency-frequency syndrome:results of a phase 2 controlled study. 2004 Congress of the International Continence Society. August 25 27, 2004. Paris, France. Abstract 142. 2004.
87 Cardozo L, Hessdorfer E, Milani R, et al. Solifenacin in the treatment of urgency and other symptoms of overactive bladder: results from a randomized, double-blind, placebo-controlled, rising-dose trial. BJU Int. Nov. 2008;102(9):1120-7. [pmid: 18990175].
88 Rentzhog L, Stanton SL, Cardozo L, et al. Efficacy and safety of tolterodine in patients with detrusor instability: a dose-ranging study. Br J Urol. Jan. 1998;81(1):42-8. [pmid: 9467475].
89 Malone-Lee JG, Walsh JB, Maugourd MF. Tolterodine: a safe and effective treatment for older patients with overactive bladder. J Am Geriatr Soc. Jun. 2001;49(6):700-5. [pmid: 11454106].
90 Jacquetin B, Wyndaele J. Tolterodine reduces the number of urge incontinence episodes in patients with an overactive bladder. Eur J Obstet Gynecol Reprod Biol. Sep. 2001;98(1):97-102. [pmid: 11516807].
91 Khullar V, Hill S, Laval KU, et al. Treatment of urge-predominant mixed urinary incontinence with tolterodine extended release: a randomized, placebo-controlled trial. Urology. Aug. 2004;64(2):269-74. discussion 74-5. [pmid: 15302476].
92 Rudy D, Cline K, Harris R, et al. Multicenter phase III trial studying trospium chloride in patients with overactive bladder. Urology. Feb. 2006;67(2):275-80. [pmid: 16461077].
93 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Medical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. 2007. www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. June 25 2010.
94 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. 2007. www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. June 25 2010.
95 Chapple CR, Abrams P. Comparison of darifenacin and oxybutynin in patients with overactive bladder: assessment of ambulatory urodynamics and impact on salivary flow. Eur Urol. Jul. 2005;48(1):102-9. [pmid: 15936869].
96 Appell RA, Sand P, Dmochowski R, et al. Prospective randomized controlled trial of extended-release oxybutynin chloride and tolterodine tartrate in the treatment of overactive bladder: results of the OBJECT Study. Mayo Clin Proc. Apr. 2001;76(4):358-63. [pmid: 11322350].
97 Armstrong RB, Luber KM, Peters KM. Comparison of dry mouth in women treated with extended-release formulations of oxybutynin or tolterodine for overactive bladder. Int Urol Nephrol. 2005;37(2):247-52. [pmid: 16142551].
98 Appell RA. Clinical efficacy and safety of tolterodine in the treatment of overactive bladder: a pooled analysis. Urology. Dec. 1997;50(6A Suppl):90-6. discussion 7-9. [pmid: 9426760].
99 Zellner M, Madersbacher H, Palmtag H, et al. Trospium chloride and oxybutynin hydrochloride in a german study of adults with urinary urge incontinence: results of a 12-week, multicenter, randomized, double-blind, parallel-group, flexible-dose noninferiority trial. Clin Ther. Nov. 2009;31(11):2519-39. [pmid: 20109997].
100 Halaska M, Ralph G, Wiedemann A, et al. Controlled, double-blind, multicentre clinical trial to investigate long-term tolerability and efficacy of trospium chloride in patients with detrusor instability. World J Urol. May. 2003;20(6):392-9. [pmid: 12811500].
101 Pharmaceutical Research and Manufacturers of America. Solifenacin in a flexible dose regimen with tolterodine as an active comparator in a double-blind, double-dummy, randomized overactive bladder symptom trial (STAR). www.clinicalstudyresults.org/documents/company-study_8350_0.pdf. June25 2010.
102 Choo MS, Lee JZ, Lee JB, et al. Efficacy and safety of solifenacin succinate in Korean patients with overactive bladder: a randomised, prospective, double-blind, multicentre study. Int J Clin Pract. Nov. 2008;62(11):1675-83. [pmid: 19143854].