# Methods

## Bayesian Approach

For Bayesian analyses, hierarchical statistical meta-analysis for multiple treatment comparisons with binary outcomes, which has a long history in the literature,22-26 was used to address the research questions. We began by fitting four logit models initially proposed by Lu and Ades,25 who suggest a fully Bayesian hierarchical approach27 to estimate a relative effect of two treatments, using a log odds ratio of the magnitude of the two effects in the binary case.

We assume that the data from each study follows a binomial distribution. That is,

r_ik_ ∼ Bin(n_ik_, p_ik_), i = 1, 2, …, I, k = 1, 2, …, K,

where r_ik_ is the total number of events, n_ik_ is the total number of subjects, and p_ik_ is the probability of the outcome in the k^th^ treatment arm from the i^th^ study, with k = 1 for the placebo arm. Logistic regression is commonly used to fit this type of data. The model can be written as

logit(p_ik_) = μ_iB_ + Δ_Bk_,

where B represents a baseline treatment (the treatment assigned the smallest k value in each study, and usually placebo), μ_iB_ is the effect of the baseline treatment in the i^th^ study, and Δ_Bk_ is the log odds ratio between the k^th^ treatment and the baseline treatment. For inference, we define d_k_ as the log odds ratio between treatment k and placebo, with d_1_ = 0, and the model above can be replaced to

logit(p_ik_) = μ_iB_ + d_k_ - d_B_,

where Δ_Bk_ is obtained from d_k_ - d_B_. Since d_k_ is the parameter compared to placebo, this can be used for our inferences regarding estimation and ranking of the treatment effects.

### Models

Our first three models are fitted under the assumption of evidence consistency; namely, that the estimated effect sizes arising from direct and indirect comparisons are the same. For example, when we compare treatments 2 and 3, we assume we can define Δ_23_ = Δ_3C_ – Δ_2C_, where C indicates the common comparator treatment. We first fit a purely fixed effects model that further assumes all studies estimate the same effect size, and therefore there is no variability (heterogeneity) between studies. In this model, we assume the log odds ratios, Δ_Bk_, are the same in each study.

To allow heterogeneity between studies, random effects models may be considered. In this approach, Δ_Bk_ is replaced with δ_iBk_, which represents a log odds ratio between treatment k and B in the i^th^ study, and we assume an independent normal specification for the δ_iBk_, i.e.,

δ_iBk_ ∼ N(d_k_ - d_B_, σ^2^).

By assigning a distribution to δ_iBk_, the model can capture the variability among studies. In this random effects model, we assume homogeneous variance σ^2^ across all k treatments; we call this homogeneous random effects model. Alternatively, we can introduce heterogeneous variances σ_Bk_^2^ rather than σ^2^ in the above distribution across treatments, called heterogeneous random effects model. For a multi-arm trial, there are more than two log odds ratios, and one can account for correlations among them. In this case, we assume δ_i_ vector follows a multivariate normal distribution with common correlation of 0.5 among treatment, and we used a conditional normal distribution for each element of δ_i_ (see Appendix A).25

Our last Bayesian model allows for evidence inconsistency by adding a set of terms called w-factors into the model. This approach captures the discrepancy between direct and indirect comparisons between two treatments (say, 2 and 3) as

Δ_23_ = Δ_3C_ − Δ_2C_ + w_C32_,

where w_C32_ is the w-factor between drugs 2 and 3 through the common comparator treatment C. One can only define the w-factor when the three relative effects (Δ_23_, Δ_3C_, and Δ_2C_ in the above equation) are estimable from independent studies. Here, we assume homogeneous variance for random effects and denote this model as inconsistency random effects model. Our data permit addition of two inconsistency factors for the UI improvement outcome (w_137_ and w_147_) and six w-factors for the discontinuation outcome (w_124_, w_137_, w_147_, w_148_, w_156_, and w_167_). Note that we number the drugs alphabetically except for placebo; i.e., placebo is drug number 1, darifenacin is 2, fesoterodine is 3, and so on. For the continence outcome, we cannot fit this model because no inconsistency w-factors are identified by these data; there are not enough studies having independent sources of direct and indirect comparisons to make these factors estimable.

### Prior Distributions

#### Noninformative Prior

In Bayesian analysis, prior information can be explicitly incorporated. We investigate two sets of prior distribution: one fully noninformative (or “flat”) prior and another that encourages shrinkage of the random effects toward their grand means. In the first approach, which we term “Bayes1,” the μ_iB_ and d_k_ are assumed to have a normal prior distribution with mean 0 and variance 10000, a specification that is very vague (though still proper) and essentially treats them as distinct, fixed effects. For the standard deviation σ in a homogeneous random effects model, a Uniform (0.01, 2) prior is adopted. For the heterogeneous model, a more complex prior for σ_Bk_ is introduced; namely, we set logσ_xy_ = logσ_0_ + υ_xy_, (x, y = 1, …, K) where σ_0_ ∼ Uniform (0.01, 2), υ_xy_ ∼ N(0, ψ^2^), and ψ is a constant chosen to reflect a certain amount of heterogeneity among arms and we pick 0.347.^25^ By adopting this prior, we can selectively estimate σ_xy_; that is, we can obtain the posterior of σ_xy_ when there are data on the relation between two treatments, x and y, but our model does not provide (or require) the posterior of σ_xy_ when such data are not observed. For our inconsistency model, the w-factor has a N(0, σ_w_^2^) where σ_w_ ∼ Uniform (0.01, 2). Here, the upper bound of uniform priors, 2, is large enough to be noninformative since a standard deviation for log odds ratio is very small.

#### Shrinkage Prior

Turning to the second prior (“Bayes2”), we introduce one more hierarchy for the baseline effect μ_iB_ to shrink toward the grand mean (m_B_). Under this prior, the μ_iB_ are distributed N(m_B_, τ^2^), where the hyperparameters m_B_ and τ have N(0, 10000) and Uniform (0.01, 2) priors, respectively. Other parameters remain the same as in the noninformative prior case.

### Model Selection

Regarding methods for Bayesian model choice, the Deviance Information Criterion (DIC) is a hierarchical modeling generalization of the familiar Akaike Information Criterion (AIC) often used in scenario like ours.28 DIC can be calculated by summing , a measure of goodness of fit having a posterior predictive interpretation, and pD, an effective number of parameters capturing overall model “size,” a quantity inappropriately measured by AIC due to the presence of random effects. Smaller values of DIC correspond to preferred models. A DIC difference of five or more is generally regarded as practically meaningful.27

### Decisionmaking

#### Probability of Being the Best Treatment

The primary goal of a multiple treatment comparison is to identify the best treatment. Suppose P_k_ is the marginal posterior probability of a particular event under treatment K, perhaps modeled with a logit function. Then if the event is a positive outcome we define the loss function as T_k_ = P_k_ (and for negative outcome, we set T_k_ = 1 – P_k_) so that a treatment with the smallest loss will be the best treatment. We then define the “Best1” probability as

Pr{K is the best treatment | Data} = Pr{rank(T_k_) = 1 | Data}.

#### Probability of Being Among the Two Best Treatments

Similarly, one can calculate the probability of being the first or second best treatment, denoted by “Best12,” by replacing the right hand side of the above equation with Pr{rank(T_k_) = 1 or 2 | Data}, where small ranks indicate best treatments.

## Frequentist Approach

Commercial software programs for frequentist multivariate random-effects meta-analyses have recently been developed, though they have some idiosyncrasies when handling multi-arm trials or incomparable baseline treatments.29,30 We have the same binomial distribution for data as we defined above, and can fit a fixed effects model written as

logit(p_ik_) = s_i_ + t_k_,

where s_i_ is fixed study-specific effect for baseline treatment and t_k_ is the log odds ratio between drug k and baseline treatment with t_1_ = 0.

For a random effects model, we can specify the logit model as follows:

logit(p_ik_) = s_i_ + t_k_ + v_ik_,

where the vector v_i_ of v_ik_ values has an independent multivariate normal distribution MVN(0,Ω), with K× K covariance matrix Ω. In SAS, we can fit this model using the GLIMMIX procedure with the assumption of Ω = σ^2^I_k_, where I_k_ is K× K identity matrix, but this model is not recommended. Instead, we rewrite the random effects model as the context of Lu and Ades notation.36 That is,

logit(p_ik_) = μ_i_ + δ_ik_ -

where δ_i1_ = 1 for all i and (δ_i2_, …, δ_iK_)^T^ ∼ MVN((d_2_, …, d_K_)^T^, Σ), with (K-1) × (K-1) covariance matrix Σ. In this notation, we have Ω = AΣA^T^, where A is a K × (K-1) matrix and the (i,j)th element of the A is A_ij_ = I(i = j+1) – (1/K), where I denotes the indicator function. One can assign a certain structure for Σ, but many authors recommend a simple structure such as homogeneous variance and 0.5 correlation across all arms. We refer to this model as the frequentist homogeneous random effects model. Please see Jones, et al.,30 for details of the covariance matrix structure.

We can loosen the homogeneous variability assumption and fit a heterogeneous random effects model using a frequentist approach.29 The model can be specified as logit(p_ik_) = μ_i_ + δ_ik_ with δ_i1_ = 0 for all i, and (δ_i2_, …, δ_iK_)^T^ ∼ MVN((d_2_, …, d_K_)^T^, Σ). Here, Σ is a unstructured (K-1) × (K-1) covariance matrix. We can estimate Σ by likelihood based methods provided the data contain at least some information on every drug-by-drug relation. We can fit this model via Stata (Statistics/Data analysis, 12)31 but, unfortunately, Stata cannot fit this model with our UI data since the data is too sparse to estimate all elements of the covariance matrix.

A final, rather crude tool for ranking treatments is the number needed to treat (NNT),32 which is the expected number of patients required to achieve one event of the outcome using the pooled absolute risk difference.33,34 Although we only use studies having placebo as the baseline arm to calculate NNT, this number is sometimes helpful to physicians in providing clinical understanding.

All of our Bayesian results were obtained from the WinBUGS software,35 using 10000 Markov chain Monte Carlo (MCMC) samples after a 5000-sample algorithm burn-in. To check MCMC convergence, we used standard diagnostics, including trace plots and lag 1 sample autocorrelations. After discovering only mild lag 1 autocorrelations and attractive trace plots, we decided to use only a single MCMC chain, run for 5000 burn-in and 10000 production samples to save time. All frequentist calculations were performed using SAS 9.2 software to obtain maximum likelihood estimators with 95 percent confidence limits by using Gaussian quadrature approximation approach.36