# Introduction

There is growing interest in assessing the relative effects of treatments by comparing one with another.1-3 Because few studies are typically available to provide evidence from direct head-to-head comparisons; we must frequently rely on indirect comparisons that use statistical techniques to estimate the treatment effects from studies of each given treatment against controls under an assumption of consistency.4-8 The problems with such systematic reviews, meta-analysis, and synthesis in general are that the circumstances of each study and the samples examined may vary and controls may differ among studies.

A number of techniques have been proposed to address this challenge.6-8Mixed (or multiple) treatment comparisons (MTCs), sometimes called network meta-analysis, refers to methods that compare treatments by combining all available evidence from studies that form a network of evidence (including studies comparing three or more treatment arms) in the absence of direct head-to-head comparisons. By synthesizing direct and indirect comparisons, we can improve the precision of estimates for treatment effects. While frequentist methods for MTCs certainly exist, they become increasingly difficult to fit less constrained models. A Bayesian analysis can easily construct such complicated models with less assumptions and permits explicit posterior inference regarding the probability that each treatment is “best” for a specific outcome.9-11

Two major issues to be considered in MTC meta-analysis are statistical heterogeneity and evidence inconsistency.11-13 Statistical heterogeneity represents effect size variability between studies. Since each study is conducted under different conditions and populations, study-specific effect sizes may vary even when they are drawn from an underlying population of study effects that has a common mean. Evidence inconsistency is another source of incompatibility that arises between direct and indirect comparisons. In many MTCs, it is possible to make both direct and indirect comparisons for some pairs of treatments. When discrepancies exist between direct and indirect comparisons in terms of size and directionality, these deviations are called evidence inconsistency.

We conducted a systematic literature review that analyzed clinical comparative efficacy of pharmacological treatments for urgency urinary incontinence (UI) in adult women.14 Urgency UI is defined as involuntary loss of urine associated with the sensation of a sudden, compelling urge to void that is difficult to defer.15 Continence (complete voluntary control of the bladder) has been considered a primary goal in UI treatment16,17 and is the most important outcome associated with quality of life in women with UI.18 We synthesized rates of continence, improvements in UI, and discontinuation of the treatments due to adverse events (AE) of drugs from 83 randomized controlled trials (RCTs).14 This review utilized traditional frequentist meta-analysis techniques and concluded that drugs for urgency UI have comparable efficacy, and that the magnitude of the benefits from such drugs is small. As such, treatment decisions should be made based on comparative safety of the drugs. Few head-to-head trials were available to provide direct estimates of the comparative efficacy of the drugs.

In this report we introduce general hierarchical models to fit such data and applied both Bayesian and frequentist approaches to estimate the comparative efficacy and safety of selected drugs.19,20 Also, we introduce more complex Bayesian hierarchical models that account for evidence inconsistency. We compare the frequentist and Bayesian approaches and provide tools to find the best treatment by using some metrics and clinically useful summary statistics that have meaning for patients and practitioners.

## Data

We reviewed studies from 1966 to November 2011. Search strategies are described elsewhere.14 We included RCTs that combined men and women if they reported outcomes in women separately or included more than 75 percent women. We excluded studies of children, adolescents, or men, studies of incontinence caused by neurological disease, and studies of dual fecal and urinary incontinence. We considered urgency UI cases. Most studies did not report the inclusion of mixed UI but some trials included patients with mixed UI as well as urgency UI. We did not find consistent statistically significant effect modification via investigation of whether inclusion of mixed UI modified the effects of the drugs on the outcomes. All trials enrolled patients with overactive bladder (OAB), and all examined drugs were approved by the U.S. Food and Drug Administration (FDA) for OAB. We pooled the trials that reported UI at baseline and also those trials that reported UI-related outcomes (such as OAB) along with UI, and did not find evidence of incomparability across these two groups.

Following FDA and other professional guidelines,17,21 we focused on patient-centered outcomes and considered only three outcomes: continence, improvement in UI, and discontinuation due to AE, as defined in Table 1. In contrast with previously published Cochrane reviews that combined continence or improvement in UI as one outcome, we analyzed better defined continence separately from improvement in UI. We used discontinuation due to AE as our safety endpoint because this addressed women's perception of the burden and seriousness of the adverse effects, as well as adherence to the treatments. When a woman stops taking a drug due to intolerable adverse effects, no further clinical decisions can be made regarding the drug that caused these effects.

Table 1 Definitions of urinary incontinence and treatment outcomes

Outcomes | Definition
Continence | Absence of any involuntary leakage of urine Author's reports of cure, absence of incontinent episodes in bladder diaries, negative pad stress, or no abnormalities noted on urodynamics
Improvement in UI | Reduction frequency and severity of incontinence episodes by >50% Reduction in pad stress test by >50% Reduction in restrictions of daily activities due to incontinence Women's perception of improvement in their bladder condition
Discontinuation of treatment due to adverse effect | Subject refusal to continue treatment due to adverse effects or physician decision to withdraw treatment due to adverse effects

Regarding dosage selection, not all studies had the same dose levels, leading to possible heterogeneity, but for a specific drug, a majority of the studies had the same dose level, while a few studies investigated different dose levels. However, we did not consider separate dose levels as separate treatments since our data were too sparse. Most studies investigated only one dose; there were just one or two studies considering multi-dose levels; in these cases, we selected the higher, more prevalent dose level.

Among 83 RCTs, 65 studies are included for our analysis. Table 2 displays the data, where the information in each cell takes the form ‘continence, UI improvement, discontinuation of the study; sample size’, with an “N” indicating no response in that category. Figure 1 exhibits the network between drugs for each outcome. The size of each node represents the number of studies investigating the drug, and the thickness of each edge corresponds to the total number of samples for the relation. There are 19 studies for continence, 28 studies for the UI improvement outcome, and 47 studies for discontinuation. Panel (a) shows that none of the studies for the continence outcome included darifenacin as a treatment arm. Panel (c) displays much more complex network structure for the discontinuation outcome, including several drug-to-drug comparisons.

Table 2 Raw UI data

Study | placebo | darifenacin | fesoterodine | oxybutynin | propiverine | solifenacin | tolterodine | trospium
Kaplan, 2010^38^ | 258, 287, 10; 480 | | 609, 709, 48; 963 | | | | 566, 654, 29; 974
NCT00444925^39^ | 138, 32, 6; 337 | | 396, 102, 44; 685 | | | | 358, 79, 28; 690
Junemann, 2006^40^ | 77, 94, 1; 202 | | | | 211, 264, 11; 391
Zinner, 2004^41^ | 29, 141, 15; 261 | | | | | | | 55, 186, 23; 262
Goode, 2004 42 | 8, 18, N; 65 | | | 15, 33, N; 67
Moore, 1990^43^ | 0, 1, N;25 | | | 5, 10, N;28
Dorschner, 2000^44^ | 15, 11, N; 49 | | | | 24, 19, N; 49
Vardy, 2009^45^ | 36, 109, N;382 | | | | | 48, 196, N;386
Staskin, 2009^46^ | 69, N, 13;400 | | | 108, N, 19;389
Chu, 2009^47^ | 80, N, 18;332 | | | | | 119, N, 37;340
Cardozo, 2006^48^ | 266, N, 40; 781 | | | | | 405, N, 51; 778
Staskin, 2006^49^ | 122, N, 19; 430 | | | | | 184, N, 31; 452
Karram, 2009^50^ | 93, N, 17;367 | | | | | 133, N, 24;372
Sand, 2009^51^ | 103, N, 18;505 | | | | | | | 163, N, 24;484
Staskin, 2007^52^ | 34, N, 11;303 | | | | | | | 61, N, 12;298
Herschorn, 2010^53^ | N, 113, 6;334 | | N, 293, 44;679 | | | | N, 256, 28;684
Homma, 2003^54^ | N, 31, 11;122 | | | N, 129, 42;244 | | | N, 100, N;239
Abrams, 1998^55^ | N, 27, 7;57 | | | N, 58, 20;118 | | | N, 59, 10;118
Steers, 2005^56^ | N, 60, 4;127, 41 | N, 160, 6;268, 160
Hill, 2006^57^ | N, 15, 3;109 | N, 28, 2;108
Chapple, 2007^58^ | N, 47, 9;133 | N, 122, 12;266
Dmochowski, 2010^59^ | N, 137, 21;445 | | N, 182, 34;438
Thuroff, 1991^60^ | N, 15, 0;52 | | | N, 26, 2;63
Herschorn, 2008^61^ | N, 64, 2;207 | | | | | | N, 156, 12;410
Lee, 2002^62^ | | | | N, 53, 18; 116 | | | N, 50, 11; 112
Lehtoranta, 2002^63^ | 2, N, N; 9 | | | 4, N, N; 9
Rogers, 2008^64^ | 89, N, N;211 | | | | | | 115, N, N;202
Malone-Lee, 2009^65^ | 26, N, N;142 | | | | | | 41, N, N;165
Dmochowski, 2008^66^ | 58, N, N; 284 | | | | | | | 95, N, N; 280
Sand, 2009^67^ | N, 167, N;430 | | N, 291, N;452 | | | | N, 140, N;227
Madersbacher, 1999^68^ | N, 43, N;72 | | | N, 116, N;145
Johnson, 2005^69^ | N, 1, N;38 | | | N, 4, N;46
Wang, 2006^70^ | N, 0, N;21 | | | N, 2, N;23
Szonyi, 1995^71^ | N, 16, N;29 | | | N, 22, N;28
Lee, 2010^72^ | N, 12, N;88 | | | | N, 55, N;176
Toglia, 2009^73^ | N, 206, N;367 | | | | | N, 260, N;372
Kelleher, 2002^74^ | N, 218, N;508 | | | | | | N, 294, N;507
Rogers, 2009^75^ | N, 58, N;211 | | | | | | N, 79, N;202
Staskin, 2004^76^ | N, 8, N;326 | | | | | | | N, 5, N;327
Zinner, 2005^77^ | N, N, 0;19 | N, N, 1;19 | | N, N, 4;19
Chapple, 2007^78^ | N, N, 6;285 | | N, N, 14;288 | | | | N, N, 9;290
Drutz, 1999^79^ | N, N, 4; 56 | | | N, N, 23;112 | | | N, N, 7; 109
Yamaguchi, 2007^80^ | N, N, 11;406 | | | | N, N, 26;402 | N, N, 26;385
Chapple, 2004^81^ | N, N, 10;267 | | | | | N, N, 7;269 | N, N, 5;266
Chapple, 2004^82^ | N, N, 2;164 | N, N, 3;229
Zinner, 2006^83^ | N, N, 10;225 | N, N, 17;214
U.S. Food and Drug Administration, 2004^84,85^ | N, N, 4;115 | N, N, 8;112
U.S. Food and Drug Administration, 2004^84,85^ | N, N, 3;164 | N, N, 3;115
Chapple,2004^86^ | N, N, 7;183 | | N, N, 22;186
Cardozo, 2008^87^ | N, N, 4;224 | | | | | N, N, 15;641
Rentzhog, 1998^88^ | N, N, 3;13 | | | | | | N, N, 2;67
Malone-Lee, 2001^89^ | N, N, 1;74 | | | | | | N, N, 7;73
Jacquetin, 2001^90^ | N, N, 1;51 | | | | | | N, N, 2;103
Khullar, 2004^91^ | N, N, 16;285 | | | | | | N, N, 26;569
Rudy, 2006 92 | N, N, 15;329 | | | | | | | N, N, 24;329
U.S. Food and Drug Administration, 2007^93,94^ | N, N, 8;284 | | | | | | | N, N, 18;280
U.S. Food and Drug Administration, 2007^93,94^ | N, N, 11;303 | | | | | | | N, N, 12;298
Chapple, 2005^95^ | | N, N, 1;13 | | N, N, 2;12
Appell, 2001^96^ | | | | N, N, 14; 185 | | | N, N, 15; 193
Armstrong, 2005^97^ | | | | N, N, 20;391 | | | N, N, 19;399
Appell, 1997^98^ | | | | N, N, 70;349 | | | N, N, 2;121
Zellner, 2009^99^ | | | | N, N, 61;830 | | | | N, N, 47;828
Halaska, 2003^100^ | | | | N, N, 3;90 | | | | N, N, 4;267
Pharmaceutical Research and Manufacturers of America101 | | | | | | N, N, 25;593 | N, N, 23;607
Choo, 2008^102^ | | | | | | N, N, 7;119 | N, N, 2;118

Note: Each cell lists counts for ‘continence, UI improvement, discontinuation of the study; sample size’, with ‘N’ indicating no response in that category.

Figure 1 Network graphs of UI data for each outcome

Note: The size of each node represents the number of studies investigating the drug, and the thickness of each edge implies the total number of samples for the relation.

Figure 1 is a network graph depicting the relations of drugs among studies in the UI data for each outcome; (a) continence, (b) UI improvement, and (c) discontinuation due to AE. In this figure, each drug is listed with the proper size of node indicating the number of studies investigating the drug, and some nodes are connected if the data include the relations. The thickness of each edge implies the total number of samples for the relation. Panel (a) has no node for Darifenacin, every nodes except Darifenacin are connected to placebo, and Tolterodine and Fesoterodine are connected. The edge between placebo and Solifenacin is thickest, and Placebo and Trospium have large nodes. In Panel (b), all nodes are connected to placebo, and Tolterodine is connected to Fesoterodine and Oxybutynin. The edges between placebo and Fesoterodine, placebo and Tolterodine, and Tolterodine and Fesoterodine are thick. Placebo has the largest node followed by Tolterodine. In Panel (c), all nodes are connected to placebo, Tolterodine is connected to Fesoterodine, Oxybutynin, and Solifenacin, Trospium and Darifenacin are connected to Oxybutynin, and Solifenacin is connected to Propiverine. The edges between placebo and Fesoterodine, placebo and Solifenacin, placebo and Tolterodine, and Tolterodine and Fesoterodine are thick. Placebo has the largest node followed by Tolterodine.