# Discussion

The main objective of this report has been to compare methodologies between frequentist and Bayesian, rather than offer a full comparative clinical assessment. Our results indicate that Bayesian methods are more flexible than frequentist methods, as well as providing substantially more information useful for clinicians and health policymakers. Theoretically, Bayesian methods are appealing due to their more rigorous mathematical foundation and their ability to incorporate all available sources of information in a model-based framework, rather than simply attempt to combine p-values in some way. From a more practical point of view, Bayesian methods offer direct probability statements about patient-centered outcome variables, such as the probability that one drug is the best or among the top two drugs for an indication, or the probability of experiencing a particular endpoint given the patient takes a particular drug. By contrast, frequentist analyses rely on traditional notions of statistical significance, and therefore do not provide an estimate of the probability of being the best drug. The Bayesian methods remedy this shortcoming, leading to more practical recommendations, though we caution that the ranks shown in Figure 3 do not come with associated standard errors, and so judging the significance of the differences between drugs must come from the log-odds ratios and Best12 probabilities in Tables 3–5.

Thanks to methodological and computational development in frequentist MTCs, we can fit frequentist fixed and random effects models comparable to Bayesian models. However, there are some limitations in the frequentist analysis. Handling study arms with zero events is always problematic, and our UI data contain such studies. One can augment the data by adding one individual with 0.5 successes to an arm containing zero events, or simply exclude studies with no events at all, but both methods have potentially harmful impacts on asymptotic approximations. When we fit the heterogeneous random effects model in Stata, we have to manipulate the dataset to make all studies have the same baseline treatment (say, placebo) by including 0.01 artificial individuals and 0.001 artificial successes for the missing placebo arms. Also, when we have sparse data, we cannot fit this model since there is not enough information to estimate all the elements of the unstructured covariance matrix, while the Bayesian method remains feasible since it does not include any inestimable elements of the covariance matrix. To measure inconsistency, the cross-validation method is used in frequentist analysis; i.e., we can estimate log odds ratios from studies including direct comparisons and indirect comparisons separately, and compare these quantities. However, Bayesian analysis allows us to measure the amount of inconsistency statistically with w-factors. In frequentist analysis, the estimates of random effect variability, σ, are always smaller than in Bayesian analysis (in the UI data analysis, σ for continence and discontinuation outcomes are close to zero). Also, the standard errors of the log odds ratios are slightly smaller than from Bayesian models, leading to more conservative conclusions. These findings are similar the those of Jones, et al.30

In the specific context of our UI data, both frequentist and Bayesian meta-analyses conclude that most of the drugs were better than placebo in achieving continence and improving UI. Differences in efficacy among the drugs are often insignificant, but the Bayesian probabilities of being among the top two most efficacious (or safest) drugs may be of practical import. Even though our Bayesian and frequentist odds ratios do not show many statistically significant differences between study drugs in the odds of continence or improving UI, we are able to identify the drugs that are more efficacious, as well as those having the highest odds of discontinuation due to adverse effects. Combining these sets of results enables an informed decision as to which drugs should be used, based on a joint assessment of their probabilities of being the most effective and safest. Of course, a sensible threshold for the probability for being the most effective and safe drug may vary depending on the topic and the appropriateness of the model and prior, which may of course be checked statistically. For example, although drugs can be ranked based on Best12 probabilities, the differences between drugs in terms of other parameters such as log odds ratio could be very small, and the ranking can thus be overinterpreted.

Both our Bayesian and frequentist analyses utilized random effects, and thus avoided the assumption of common drugs' effect sizes across trials. Clinicians and patients need to know rates of the benefits and harms to make informed decisions. The NNTs derived from frequentist analyses provide useful information for clinicians, but their interpretation is often difficult for patients. Bayesian analysis provides an intuitively appealing probability of the outcome that easily leads to identifying the best and the worst treatment for each measure of benefit or harm. A single estimate of the balance between benefits and harms would be the most simple and useful information for making informed decisions in clinical settings. Also, when there are multiple outcomes (as in the UI data), we could choose sensible weights for each outcome to find the best compromising drug in terms of one's preference (i.e., a clinician might well put more weight on the safety outcome.

Although Bayesian methods provide many promising features, we can still improve our analysis. In this analysis, we only consider noninformative and shrinkage priors. While our shrinkage prior is partially informative, we do not incorporate specific prior information regarding efficacy or safety for any drug due to limited information about natural history of urgency UI. We could construct informative priors based upon either external data or expert opinion, possibly leading to better model fitting. For decision making, Best12 probabilities are used to find the best drug with respect to each outcome, but one could set up other metrics to evaluate drug performance, and the Bayesian framework can easily handle this. Also, we encourage comprehensive conclusions based on various tools, not solely based on Best12 probabilities from a single model. For example, a drug could be a winner in terms of Best12, but its odds ratio may not imply significant differences from other drugs.

Our study itself has several limitations. We assume patients assigned to different drugs across studies have similar baseline characteristics, so the potential impact of differential baselines could exist. Also, we do not adjust for study quality (say, due to difference in randomization methods or publication bias), role of the drug within the RTCs, doses of the drugs, age of the women, their baseline UI severities, or their natural histories of urgency UI. Meta-regression is one of methods to incorporate those study-level characteristics, and we hope to apply this method in a future manuscript. Differentiation between immediate release (IR) and extended release (ER) formulations could also change our findings, but we lack sufficient data to estimate this effect.

Regarding the definition of UI improvement, although our studies have various definitions of UI improvement potentially leading to clinical heterogeneity, our random effects models, handling heterogeneity between studies, imply small study-to-study variability. We analyzed how differences in definitions of improved UI can influence the treatment effects, but found them likely to be small. For instance, the studies that defined improvement as a reduction of 75 percent in UI episodes (instead of 50 percent) lead to similar relative risks and absolute risk differences. Our choice of the safety endpoint (discontinuation due to AE) could be problematic because the definitions could be widely different among study protocols. We also do not analyze all available adverse effects from the drugs, such as dry mouth or constipation. Patients may have differential sensitivity to specific adverse events, but to estimate this individualized effect, patient-level data with individual-level covariates are required.

Broad recommendations regarding choice among Bayesian and frequentist models await simulation studies where performance and rankings of the methods can be compared in various settings where the true states of nature (say, that the indirect evidence is inconsistent with the direct) are known. Finally, fully Bayesian methods for formally combining both efficacy and safety data into a single decision rule would be a significant aid in making a sensible overall decision. We hope to address these and other methodological issues in a future publication.