# Randomized Controlled Clinical Trials That Examined Drugs for Urgency Urinary Incontinence

## References for Appendix C

1 Abrams P, Freeman R, Anderstrom C, et al. Tolterodine, a new antimuscarinic agent: as effective but better tolerated than oxybutynin in patients with an overactive bladder. Br J Urol. Jun. 1998;81(6):801-10. [pmid: 9666761].
2 Appell RA. Clinical efficacy and safety of tolterodine in the treatment of overactive bladder: a pooled analysis. Urology. Dec. 1997;50(6A Suppl):90-6. discussion 7-9. [pmid: 9426760].
3 Appell RA, Sand P, Dmochowski R, et al. Prospective randomized controlled trial of extended-release oxybutynin chloride and tolterodine tartrate in the treatment of overactive bladder: results of the OBJECT Study. Mayo Clin Proc. Apr. 2001;76(4):358-63. [pmid: 11322350].
4 Sand PK, Miklos J, Ritter H, et al. A comparison of extended-release oxybutynin and tolterodine for treatment of overactive bladder in women. Int Urogynecol J Pelvic Floor Dysfunct. Jul-Aug. 2004;15(4):243-8. [pmid: 15517668].
5 Burgio KL, Locher JL, Goode PS, et al. Behavioral vs drug treatment for urge urinary incontinence in older women: a randomized controlled trial. JAMA. Dec. 16. 1998;280(23):1995-2000. [pmid: 9863850].
6 Goode PS, Burgio KL, Locher JL, et al. Urodynamic changes associated with behavioral and drug treatment of urge incontinence in older women. J Am Geriatr Soc. May. 2002;50(5):808-16. [pmid: 12028165].
7 Goode PS. Behavioral and drug therapy for urinary incontinence. Urology. Mar. 2004;63(3 Suppl 1):58-64. [pmid: 15013654].
8 Cardozo L, Castro-Diaz D, Gittelman M, et al. Reductions in overactive bladder-related incontinence from pooled analysis of phase III trials evaluating treatment with solifenacin. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):512-9. [pmid: 16625311].
9 Chapple C, Van Kerrebroeck P, Tubaro A, et al. Clinical efficacy, safety, and tolerability of once-daily fesoterodine in subjects with overactive bladder. Eur Urol. Oct. 2007;52(4):1204-12. [pmid: 17651893].
10 Chapple CR, Van Kerrebroeck PE, Junemann KP, et al. Comparison of fesoterodine and tolterodine in patients with overactive bladder. BJU Int. Nov. 2008;102(9):1128-32. [pmid: 18647298].
11 Chapple C, DuBeau C, Ebinger U, et al. Darifenacin treatment of patients >or= 65 years with overactive bladder: results of a randomized, controlled, 12-week trial. Curr Med Res Opin. Oct. 2007;23(10):2347-58. [pmid: 17706004].
12 Chapple CR, Abrams P. Comparison of darifenacin and oxybutynin in patients with overactive bladder: assessment of ambulatory urodynamics and impact on salivary flow. Eur Urol. Jul. 2005;48(1):102-9. [pmid: 15936869].
13 Chapple C, Steers W, Norton P, et al. A pooled analysis of three phase III studies to investigate the efficacy, tolerability and safety of darifenacin, a muscarinic M3 selective receptor antagonist, in the treatment of overactive bladder. BJU Int. May. 2005;95(7):993-1001. [pmid: 15839920].
14 Fesoterodine a new effective and well-tolerated antimuscarinic for the treatment of urgency-frequency syndrome:results of a phase 2 controlled study. 2004 Congress of the International Continence Society. August 25-27, 2004. Paris, France. Abstract 142. 2004.
15 Chapple CR, Rechberger T, Al-Shukri S, et al. Randomized, double-blind placebo- and tolterodine-controlled trial of the once-daily antimuscarinic agent solifenacin in patients with symptomatic overactive bladder. BJU Int. Feb. 2004;93(3):303-10. [pmid: 14764127].
16 Chapple CR. Darifenacin: a novel M3 muscarinic selective receptor antagonist for the treatment of overactive bladder. Expert Opin Investig Drugs. Nov. 2004;13(11):1493-500. [pmid: 15500396].
17 Choo MS, Lee JZ, Lee JB, et al. Efficacy and safety of solifenacin succinate in Korean patients with overactive bladder: a randomised, prospective, double-blind, multicentre study. Int J Clin Pract. Nov. 2008;62(11):1675-83. [pmid: 19143854].
18 Chu F, Smith N, Uchida T. Efficacy and safety of solifenacin succinate 10 mg once Daily: A multicenter, phase III, randomized, double-blind, placebo-controlled, parallel-group trial in patients with overactive bladder. Current Therapeutic Research. December. 2009;70(6):405-20.
19 Diokno AC, Appell RA, Sand PK, et al. Prospective, randomized, double-blind study of the efficacy and tolerability of the extended-release formulations of oxybutynin and tolterodine for overactive bladder: results of the OPERA trial. Mayo Clin Proc. Jun. 2003;78(6):687-95. [pmid: 12934777].
20 Armstrong RB, Luber KM, Peters KM. Comparison of dry mouth in women treated with extended-release formulations of oxybutynin or tolterodine for overactive bladder. Int Urol Nephrol. 2005;37(2):247-52. [pmid: 16142551].
21 Chu FM, Dmochowski RR, Lama DJ, et al. Extended-release formulations of oxybutynin and tolterodine exhibit similar central nervous system tolerability profiles: a subanalysis of data from the OPERA trial. Am J Obstet Gynecol. Jun. 2005;192(6):1849-54. discussion 54-5. [pmid: 15970828].
22 Anderson RU, MacDiarmid S, Kell S, et al. Effectiveness and tolerability of extended-release oxybutynin vs extended-release tolterodine in women with or without prior anticholinergic treatment for overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):502-11. [pmid: 16724169].
23 Dmochowski RR, Peters KM, Morrow JD, et al. Randomized, double-blind, placebo-controlled trial of flexible-dose fesoterodine in subjects with overactive bladder. Urology. Jan. 2010;75(1):62-8. [pmid: 19931895].
24 Dmochowski RR, Sand PK, Zinner NR, et al. Trospium 60 mg once daily (QD) for overactive bladder syndrome: results from a placebo-controlled interventional study. Urology. Mar. 2008;71(3):449-54. [pmid: 18342185].
25 Dorschner W, Stolzenburg JU, Griebenow R, et al. Efficacy and cardiac safety of propiverine in elderly patients - a double-blind, placebo-controlled clinical study. Eur Urol. Jun. 2000;37(6):702-8. [pmid: 10828671].
26 Drutz HP, Appell RA, Gleason D, et al. Clinical efficacy and safety of tolterodine compared to oxybutynin and placebo in patients with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):283-9. [pmid: 10543335].
27 Halaska M, Ralph G, Wiedemann A, et al. Controlled, double-blind, multicentre clinical trial to investigate long-term tolerability and efficacy of trospium chloride in patients with detrusor instability. World J Urol. May. 2003;20(6):392-9. [pmid: 12811500].
28 Herschorn S, Swift S, Guan Z, et al. Comparison of fesoterodine and tolterodine extended release for the treatment of overactive bladder: a head-to-head placebo-controlled trial. BJU Int. Jan. 2010;105(1):58-66. [pmid: 20132103].
29 Herschorn S, Heesakkers J, Castro-Diaz D, et al. Effects of tolterodine extended release on patient perception of bladder condition and overactive bladder symptoms*. Curr Med Res Opin. Dec. 2008;24(12):3513-21. [pmid: 19032133].
30 Hill S, Khullar V, Wyndaele JJ, et al. Dose response with darifenacin, a novel once-daily M3 selective receptor antagonist for the treatment of overactive bladder: results of a fixed dose study. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):239-47. [pmid: 15999217].
31 Homma Y, Paick JS, Lee JG, et al. Clinical efficacy and tolerability of extended-release tolterodine and immediate-release oxybutynin in Japanese and Korean patients with an overactive bladder: a randomized, placebo-controlled trial. BJU Int. Nov. 2003;92(7):741-7. [pmid: 14616458].
32 Takei M, Homma Y. Long-term safety, tolerability and efficacy of extended-release tolterodine in the treatment of overactive bladder in Japanese patients. Int J Urol. May. 2005;12(5):456-64. [pmid: 15948744].
33 Homma Y, Kawabe K. Health-related quality of life of Japanese patients with overactive bladder treated with extended-release tolterodine or immediate-release oxybutynin: a randomized, placebo-controlled trial. World J Urol. Oct. 2004;22(4):251-6. [pmid: 15455256].
34 Jacquetin B, Wyndaele J. Tolterodine reduces the number of urge incontinence episodes in patients with an overactive bladder. Eur J Obstet Gynecol Reprod Biol. Sep. 2001;98(1):97-102. [pmid: 11516807].
35 Johnson TM 2nd, Burgio KL, Redden DT, et al. Effects of behavioral and drug therapy on nocturia in older incontinent women. J Am Geriatr Soc. May. 2005;53(5):846-50. [pmid: 15877562].
36 Junemann KP, Al-Shukri S. Efficacy and tolerability of trospium cholride and tolterodine in 234 patients with urge syndrome: a double-bline, placebo-controlled, multicentre clinical trial. Neurourol Urodyn. 2000;19:488-90.
37 Superior efficacy of fesoterodine over tolterodine with rapid onset: A prospective, head-to-head, placebo-controlled trial. Neurourology and Urodynamics. Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23-27 August 2010. 2010:29.
38 Kaplan SA, Schneider T, Foote JE, et al. Superior efficacy of fesoterodine over tolterodine extended release with rapid onset: a prospective, head-to-head, placebo-controlled trial. BJU Int. May. 2011;107(9):1432-40. [pmid: 20860717].
39 Karram MM, Toglia MR, Serels SR, et al. Treatment with solifenacin increases warning time and improves symptoms of overactive bladder: results from VENUS, a randomized, double-blind, placebo-controlled trial. Urology. Jan. 2009;73(1):14-8. [pmid: 18995887].
40 Solifenacin for overactive bladder: patient-reported outcomes from a large placebo-controlled trial. Postgrad Med. Sep. 2009;121(5):151-8. [pmid: 19820284].
41 Kelleher CJ, Reese PR, Pleil AM, et al. Health-related quality of life of patients receiving extended-release tolterodine for overactive bladder. The American journal of managed care. 2002:S608-15. [pmid: 12516955].
42 Zinner NR, Mattiasson A, Stanton SL. Efficacy, safety, and tolerability of extended-release once-daily tolterodine treatment for overactive bladder in older versus younger patients. J Am Geriatr Soc. May. 2002;50(5):799-807. [pmid: 12028164].
43 Van Kerrebroeck P, Kreder K, Jonas U, et al. Tolterodine once-daily: superior efficacy and tolerability in the treatment of the overactive bladder. Urology. Mar. 2001;57(3):414-21. [pmid: 11248608].
44 Dmochowski R, Kreder K, MacDiarmid S, et al. The clinical efficacy of tolterodine extended-release is maintained for 24 h in patients with overactive bladder. BJU Int. Jul. 2007;100(1):107-10. [pmid: 17552957].
45 Wein AJ, Khullar V, Wang JT, et al. Achieving continence with antimuscarinic therapy for overactive bladder: effects of baseline incontinence severity and bladder diary duration. BJU Int. Feb. 2007;99(2):360-3. [pmid: 17155987].
46 Landis JR, Kaplan S, Swift S, et al. Efficacy of antimuscarinic therapy for overactive bladder with varying degrees of incontinence severity. J Urol. Feb. 2004;171(2 Pt 1):752-6. [pmid: 14713803].
47 Swift S, Garely A, Dimpfl T, et al. A new once-daily formulation of tolterodine provides superior efficacy and is well tolerated in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):50-4. discussion 4-5. [pmid: 12601517].
48 Freeman R, Hill S, Millard R, et al. Reduced perception of urgency in treatment of overactive bladder with extended-release tolterodine. Obstet Gynecol. Sep. 2003;102(3):605-11. [pmid: 12962951].
49 Khullar V, Hill S, Laval KU, et al. Treatment of urge-predominant mixed urinary incontinence with tolterodine extended release: a randomized, placebo-controlled trial. Urology. Aug. 2004;64(2):269-74. discussion 74-5. [pmid: 15302476].
50 DuBeau CE, Khullar V, Versi E. “Unblinding” in randomized controlled drug trials for urinary incontinence: Implications for assessing outcomes when adverse effects are evident. Neurourol Urodyn. 2005;24(1):13-20. [pmid: 15570576].
51 Lee KS, Lee HW, Choo MS, et al. Urinary urgency outcomes after propiverine treatment for an overactive bladder: the ‘Propiverine study on overactive bladder including urgency data’. BJU Int. Jun. 2010;105(11):1565-70. [pmid: 19912183].
52 Lee JG, Hong JY, Choo MS, et al. Tolterodine: as effective but better tolerated than oxybutynin in Asian patients with symptoms of overactive bladder. Int J Urol. May. 2002;9(5):247-52. [pmid: 12060436].
53 Lehtoranta K, Tainio H, Lukkari-Lax E, et al. Pharmacokinetics, efficacy, and safety of intravesical formulation of oxybutynin in patients with detrusor overactivity. Scand J Urol Nephrol. Feb. 2002;36(1):18-24. [pmid: 12002352].
54 Madersbacher H, Halaska M, Voigt R, et al. A placebo-controlled, multicentre study comparing the tolerability and efficacy of propiverine and oxybutynin in patients with urgency and urge incontinence. BJU Int. Oct. 1999;84(6):646-51. [pmid: 10510109].
55 Malone-Lee JG, Al-Buheissi S. Does urodynamic verification of overactive bladder determine treatment success? Results from a randomized placebo-controlled study. BJU Int. Apr. 2009;103(7):931-7. [pmid: 19281469].
56 Malone-Lee JG, Walsh JB, Maugourd MF. Tolterodine: a safe and effective treatment for older patients with overactive bladder. J Am Geriatr Soc. Jun. 2001;49(6):700-5. [pmid: 11454106].
57 Moore KH, Hay DM, Imrie AE, et al. Oxybutynin hydrochloride (3 mg) in the treatment of women with idiopathic detrusor instability. Br J Urol. Nov. 1990;66(5):479-85. [pmid: 2249115].
58 NCT00444925. Clinical Trial to Evaluate the Efficacy and Safety of Fesoterodine in Comparison to Tolterodine for Overactive Bladder (OAB). http://www.clinicaltrials.gov/ct2/show/NCT00444925?term=NCT00444925&rank=1.
59 Rentzhog L, Stanton SL, Cardozo L, et al. Efficacy and safety of tolterodine in patients with detrusor instability: a dose-ranging study. Br J Urol. Jan. 1998;81(1):42-8. [pmid: 9467475].
60 Rogers RG, Bachmann G, Scarpero H, et al. Effects of tolterodine ER on patient-reported outcomes in sexually active women with overactive bladder and urgency urinary incontinence. Curr Med Res Opin. Sep. 2009;25(9):2159-65. [pmid: 19601704].
61 Rogers R, Bachmann G, Jumadilova Z, et al. Efficacy of tolterodine on overactive bladder symptoms and sexual and emotional quality of life in sexually active women. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1551-7. [pmid: 18685795].
62 Rogers RG, Omotosho T, Bachmann G, et al. Continued symptom improvement in sexually active women with overactive bladder and urgency urinary incontinence treated with tolterodine ER for 6 months. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2009;20(4):381-5. [pmid: 19132285].
63 Rudy D, Cline K, Harris R, et al. Time to onset of improvement in symptoms of overactive bladder using antimuscarinic treatment. BJU Int. Mar. 2006;97(3):540-6. [pmid: 16469022].
64 Sand PK, Morrow JD, Bavendam T, et al. Efficacy and tolerability of fesoterodine in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2009;20(7):827-35. [pmid: 19495545].
65 Nitti CVW, Dmochowski R, Sand PK, et al. Efficacy, safety and tolerability of fesoterodine for overactive bladder syndrome. J Urol. Dec. 2007;178(6):2488-94. [pmid: 17937959].
66 Sand PK, Dmochowski RR, Zinner NR, et al. Trospium chloride extended release is effective and well tolerated in women with overactive bladder syndrome. Int Urogynecol J Pelvic Floor Dysfunct. 2009. Aug. 29. [pmid: 19727537].
67 Dmochowski RR, Rosenberg MT, Zinner NR, et al. Extended-release trospium chloride improves quality of life in overactive bladder. Value Health. Mar. 2010;13(2):251-7. [pmid: 19818062].
68 Staskin DR, Te AE. Short- and long-term efficacy of solifenacin treatment in patients with symptoms of mixed urinary incontinence. BJU Int. Jun. 2006;97(6):1256-61. [pmid: 16686722].
69 Staskin D, Sand P, Zinner N, et al. Once daily trospium chloride is effective and well tolerated for the treatment of overactive bladder: results from a multicenter phase III trial. J Urol. Sep. 2007;178(3 Pt 1):978-83. discussion 83-4. [pmid: 17632131].
70 Staskin DR, Harnett MD. Effect of trospium chloride on somnolence and sleepiness in patients with overactive bladder. Curr Urol Rep. Dec. 2004;5(6):423-6. [pmid: 15541209].
71 Staskin DR, Dmochowski RR, Sand PK, et al. Efficacy and safety of oxybutynin chloride topical gel for overactive bladder: a randomized, double-blind, placebo controlled, multicenter study. J Urol. Apr. 2009;181(4):1764-72. [pmid: 19233423].
72 Steers W, Corcos J, Foote J, et al. An investigation of dose titration with darifenacin, an M3-selective receptor antagonist. BJU Int. Mar. 2005;95(4):580-6. [pmid: 15705084].
73 Szonyi G, Collas DM, Ding YY, et al. Oxybutynin with bladder retraining for detrusor instability in elderly people: a randomized controlled trial. Age Ageing. 1995/07/01 ed. 1995:287-91. [pmid: 7484484].
74 Thuroff JW, Bunke B, Ebner A, et al. Randomized, double-blind, multicenter trial on treatment of frequency, urgency and incontinence related to detrusor hyperactivity: oxybutynin versus propantheline versus placebo. J Urol. Apr. 1991;145(4):813-6. discussion 6-7. [pmid: 2005707].
75 Toglia MR, Ostergard DR, Appell RA, et al. Solifenacin for overactive bladder: secondary analysis of data from VENUS based on baseline continence status. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2010;21(7):847-54. [pmid: 20339833].
76 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Solifenacin in the treatment of urgency symptoms of overactive bladder in a rising dose, randomized, placebo-controlled, double-blind trial (SUNRISE). www.clinicalstudyresults.org/documents/company-study_8351_0.pdf. June 25 2010.
77 Cardozo L, Hessdorfer E, Milani R, et al. Solifenacin in the treatment of urgency and other symptoms of overactive bladder: results from a randomized, double-blind, placebo-controlled, rising-dose trial. BJU Int. Nov. 2008;102(9):1120-7. [pmid: 18990175].
78 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Medical Review for Enablex (Clarifenacin) Extended Release Tablets. 2004. www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. June 25 2010.
79 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review for Enablex (Darifenacin Hydrobromide) Extended Release Tablets. 2004. www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-513_Enablex.cfm. June 25 2010.
80 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Medical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. 2007. www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. June 25 2010.
81 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review for Sanctura XR (Trospium Chloride) Extended Release Capsules. 2007. www.accessdata.fda.gov/drugsatfda_docs/nda/2007/022103s000TOC.cfm. June 25 2010.
82 Chapple CR, Martinez-Garcia R, Selvaggi L, et al. A comparison of the efficacy and tolerability of solifenacin succinate and extended release tolterodine at treating overactive bladder syndrome: results of the STAR trial. Eur Urol. Sep. 2005;48(3):464-70. [pmid: 15990220].
83 Chapple CR, Fianu-Jonsson A, Indig M, et al. Treatment outcomes in the STAR study: a subanalysis of solifenacin 5 mg and tolterodine ER 4 mg. Eur Urol. Oct. 2007;52(4):1195-203. [pmid: 17574730].
84 Pharmaceutical Research and Manufacturers of America. Solifenacin in a flexible dose regimen with tolterodine as an active comparator in a double-blind, double-dummy, randomized overactive bladder symptom trial (STAR). www.clinicalstudyresults.org/documents/company-study_8350_0.pdf. June 25 2010.
85 Vardy MD, Mitcheson HD, Samuels TA, et al. Effects of solifenacin on overactive bladder symptoms, symptom bother and other patient-reported outcomes: results from VIBRANT - a double-blind, placebo-controlled trial. Int J Clin Pract. Dec. 2009;63(12):1702-14. [pmid: 19930331].
86 Wang AC, Chih SY, Chen MC. Comparison of electric stimulation and oxybutynin chloride in management of overactive bladder with special reference to urinary urgency: a randomized placebo-controlled trial. Urology. Nov. 2006;68(5):999-1004. [pmid: 17113893].
87 Yamaguchi O, Marui E, Kakizaki H, et al. Randomized, double-blind, placebo- and propiverine-controlled trial of the once-daily antimuscarinic agent solifenacin in Japanese patients with overactive bladder. BJU Int. Sep. 2007;100(3):579-87. [pmid: 17669143].
88 Zellner M, Madersbacher H, Palmtag H, et al. Trospium chloride and oxybutynin hydrochloride in a german study of adults with urinary urge incontinence: results of a 12-week, multicenter, randomized, double-blind, parallel-group, flexible-dose noninferiority trial. Clin Ther. Nov. 2009;31(11):2519-39. [pmid: 20109997].
89 Bodeker RH, Madersbacher H, Neumeister C, et al. Dose escalation improves therapeutic outcome: post hoc analysis of data from a 12-week, multicentre, double-blind, parallel-group trial of trospium chloride in patients with urinary urge incontinence. BMC Urol. 2010;10:15. [pmid: 20840754].
90 Zinner N, Tuttle J, Marks L. Efficacy and tolerability of darifenacin, a muscarinic M3 selective receptor antagonist (M3 SRA), compared with oxybutynin in the treatment of patients with overactive bladder. World J Urol. Sep. 2005;23(4):248-52. [pmid: 16096831].
91 Zinner N, Susset J, Gittelman M, et al. Efficacy, tolerability and safety of darifenacin, an M(3) selective receptor antagonist: an investigation of warning time in patients with OAB. Int J Clin Pract. Jan. 2006;60(1):119-26. [pmid: 16409440].
92 Zinner N, Gittelman M, Harris R, et al. Trospium chloride improves overactive bladder symptoms: a multicenter phase III trial. J Urol. Jun. 2004;171(6 Pt 1):2311-5. quiz 435. [pmid: 15126811].