# Bugs and SAS Codes for Bayesian and Frequentist Analysis

#BUGS code for fixed effects model under the noninformative prior
#with respect to the UI improvement outcome

model {

 for(i in 1:N) {
  logit(p[i]) <- mu[s[i]] + d[t[i]] - d[b[i]]
  r[i] ∼ dbin(p[i], n[i])
 }

 for(j in 1:NS) { mu[j] ∼ dnorm(0, 0.0001) }

 d[1] <- 0
 for (k in 2:NT) {
  d[k] ∼ dnorm(0, 0.0001)
  ed[k] <- exp(d[k]) # ed is odds ratio against placebo
 }

 # pairwise ORs
 # Example: or[2,3] = odds ratio of active(2) vs. control(3)
 for (k in 1:NT) {
  for (c in 1:NT) {
   lor[k,c] <- d[k] - d[c]
   log(or[k,c]) <- lor[k,c]
  }
 }

 # ranking
 mP <- mean(mu[1:27])    # Take average of mu[]

 for (k in 1:NT) { logit(T[k]) <- mP + d[k] }
 for (k in 1:NT) {
  rk[k] <- NT + 1 - rank(T[],k)
  best1[k] <- equals(rk[k],1)
  best2[k] <- equals(rk[k],2)
  best12[k] <- best1[k] + best2[k]
 }
}

#Init
list(
d=c(NA,0,0,0,0,0,0,0),
mu=c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0)
)

#Data
#Numbers for drugs:
#1=placebo; 2=darifenacin; 3=fesoterodine; 4=oxybutynin;
#5=propiverine; 6=solifenacin; 7=tolterodine; 8=trospium
list(N=62, NS=28, NT=8)
s[]   t[]   r[]   n[]   b[]
1     1     113   334   1
1     3     293   679   1
1     7     256   684   1
2     1     32    337   1
2     3     102   685   1
2     7     79    690   1
3     1     167   430   1
3     3     291   452   1
3     7     140   227   1
4     1     287   480   1
4     3     709   963   1
4     7     654   974   1
5     1     27    57    1
5     4     58    118   1
5     7     59    118   1
6     1     31    122   1
6     4     129   244   1
6     7     100   239   1
7     1     60    127   1
7     2     160   268   1
8     1     15    109   1
8     2     28    108   1
9     1     47    133   1
9     2     122   266   1
10    1     137   445   1
10    3     182   438   1
11    1     15    52    1
11    4     26    63    1
12    1     1     25    1
12    4     10    28    1
13    1     16    29    1
13    4     22    28    1
14    1     20    65    1
14    4     37    67    1
15    1     43    72    1
15    4     116   145   1
16    1     1     38    1
16    4     4     46    1
17    1     0     21    1
17    4     2     23    1
18    1     11    49    1
18    5     19    49    1
19    1     94    202   1
19    5     264   391   1
20    1     12    88    1
20    5     55    176   1
21    1     109   382   1
21    6     196   386   1
22    1     206   367   1
22    6     260   372   1
23    1     218   508   1
23    7     294   507   1
24    1     64    207   1
24    7     156   410   1
25    1     58    211   1
25    7     79    202   1
26    1     141   261   1
26    8     186   262   1
27    1     8     326   1
27    8     5     327   1
28    4     53    116   4
28    7     50    112   4
END

#BUGS code for homogeneous random effects model under the noninformative prior
#with respect to the UI improvement outcome

model {
for (i in 1:NS) {
s[i,1] <- 0
delta[i, t[i,1]] <- 0
mu[i] ∼ dnorm(0, 0.0001)

for (k in 1:na[i]) {
     r[i,k] ∼ dbin(p[i,t[i,k]], n[i,k])
     logit(p[i,t[i,k]]) <- mu[i] + delta[i,t[i,k]]
   }

for (k in 2:na[i]) {
     delta[i,t[i,k]] ∼ dnorm(md[i,t[i,k]], taud[i,t[i,k]])
     md[i,t[i,k]] <- d[t[i,k]] - d[t[i,1]] + ss[i,k]
taud[i,t[i,k]] <- tau*2*(k-1)/k
    s[i,k] <- (delta[i, t[i,k]] - d[t[i,k]] + d[t[i,1]])
ss[i,k] <- sum(s[i, 1:k-1])/(k-1)
  }
 }

d[1] <- 0
for (k in 2:NT) {
d[k] ∼ dnorm(0,0.0001)
ed[k] <- exp(d[k]) # ed is odds ratio against placebo
 }

sd∼dunif(0.01,2)
tau<- 1/pow(sd,2)
var<- pow(sd,2)

 # pairwise ORs
 # Example: or[2,3] = odds ratio of active(2) vs. control(3)
for (k in 1:NT) {
for (c in 1:NT) {
lor[k,c] <- d[k] - d[c]
log(or[k,c]) <- lor[k,c]
  }
 }

 # ranking
mP<- mean(mu[1:27]) # Take average of mu[]

for (k in 1:NT) { logit(T[k]) <- mP + d[k] } # T=prob of each trt
for (k in 1:NT) {
rk[k] <- NT + 1 - rank(T[],k)
best1[k] <- equals(rk[k],1)
best2[k] <- equals(rk[k],2)
best12[k] <- best1[k] + best2[k]
 }
}

#Init
list(
d=c(NA,0,0,0,0,0,0,0),
sd=1,
mu=c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0)
)

#Data
list(NT=8, NS=28)

r[,1]   n[,1]   r[,2]   n[,2]   r[,3]   n[,3]   t[,1]   t[,2]   t[,3]   na[]
113     334     293     679     256     684     1       3       7       3
32      337     102     685     79      690     1       3       7       3
167     430     291     452     140     227     1       3       7       3
287     480     709     963     654     974     1       3       7       3
27      57      58      118     59      118     1       4       7       3
31      122     129     244     100     239     1       4       7       3
60      127     160     268     NA      1       1       2       NA      2
15      109     28      108     NA      1       1       2       NA      2
47      133     122     266     NA      1       1       2       NA      2
137     445     182     438     NA      1       1       3       NA      2
15      52      26      63      NA      1       1       4       NA      2
1       25      10      28      NA      1       1       4       NA      2
16      29      22      28      NA      1       1       4       NA      2
20      65      37      67      NA      1       1       4       NA      2
43      72      116     145     NA      1       1       4       NA      2
1       38      4       46      NA      1       1       4       NA      2
0       21      2       23      NA      1       1       4       NA      2
11      49      19      49      NA      1       1       5       NA      2
94      202     264     391     NA      1       1       5       NA      2
12      88      55      176     NA      1       1       5       NA      2
109     382     196     386     NA      1       1       6       NA      2
206     367     260     372     NA      1       1       6       NA      2
218     508     294     507     NA      1       1       7       NA      2
64      207     156     410     NA      1       1       7       NA      2
58      211     79      202     NA      1       1       7       NA      2
141     261     186     262     NA      1       1       8       NA      2
8       326     5       327     NA      1       1       8       NA      2
53      116     50      112     NA      1       4       7       NA      2
END

#BUGS code for heterogeneous random effects model under the noninformative prior
#with respect to the UI improvement outcome

model {
 for (i in 1:NS) {
  s[i,1] <- 0
  delta[i, t[i,1]] <- 0
  mu[i] ∼ dnorm(0, 0.0001)

 for (k in 1:na[i]) {
  r[i,k] ∼ dbin(p[i,t[i,k]], n[i,k])
  logit(p[i,t[i,k]]) <- mu[i] + delta[i,t[i,k]]
 }

 for (k in 2:na[i]) {
  delta[i,t[i,k]] ∼ dnorm(md[i,t[i,k]], taud[i,t[i,k]])
  md[i,t[i,k]] <- d[t[i,k]] - d[t[i,1]] + ss[i,k]
  taud[i,t[i,k]] <- tau[t[i,1],t[i,k]]*2*(k-1)/k
  s[i,k] <- (delta[i, t[i,k]] - d[t[i,k]] + d[t[i,1]])
  ss[i,k] <- sum(s[i, 1:k-1])/(k-1)
 }
}

d[1] <- 0
for (k in 2:NT) {
 d[k] ∼ dnorm(0,0.0001)
 ed[k] <- exp(d[k]) # ed is odds ratio against placebo
}

for(i in 1:(NT-1)) {
 for(j in (i+1):NT) {
  v[i,j] ∼ dnorm(0, 8.32)
  log(sd[i,j]) <- log(sd0) + v[i,j]
  tau[i,j] <- 1/pow(sd[i,j],2)
  var[i,j] <- pow(sd[i,j],2)
 }
}
sd0 ∼ dunif(0.01,2)
var0 <- pow(sd0,2)

# pairwise ORs
# Example: or[2,3] = odds ratio of active(2) vs. control(3)
for (k in 1:NT) {
 for (c in 1:NT) {
  lor[k,c] <- d[k] - d[c]
  log(or[k,c]) <- lor[k,c]
 }
}

# ranking
mP <- mean(mu[1:27])    # Take average of mu[]

for (k in 1:NT) { logit(T[k]) <- mP + d[k] }
for (k in 1:NT) {
 rk[k] <- NT + 1 - rank(T[],k)
 best1[k] <- equals(rk[k],1)
 best2[k] <- equals(rk[k],2)
 best12[k] <- best1[k] + best2[k]
 }
}

#Init
list(
d=c(NA,0,0,0,0,0,0,0),
sd0=1,
mu=c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0)
)

#Data are the same as in Model 2

#BUGS code for inconsistency random effects model under the noninformative prior
#with respect to the UI improvement outcome

model {
 for (i in 1:NS) {
  s[i,1] <- 0
  delta[i, t[i,1]] <- 0
  mu[i] ∼ dnorm(0, 0.0001)

  for (k in 1:na[i]) {
   r[i,k] ∼ dbin(p[i,t[i,k]], n[i,k])
   logit(p[i,t[i,k]]) <- mu[i] + delta[i,t[i,k]]
  }

  for (k in 2:na[i]) {
   delta[i,t[i,k]] ∼ dnorm(md[i,t[i,k]],  taud[i,t[i,k]])
   md[i,t[i,k]] <- dd[t[i,k],t[i,1]] + ss[i,k]
   taud[i,t[i,k]] <- tau*2*(k-1)/k
   s[i,k] <- (delta[i, t[i,k]] - dd[t[i,k],t[i,1]])
   ss[i,k] <- sum(s[i, 1:k-1])/(k-1)
  }
 }

 dd[7,3] <- d[7] - d[3] + wf[1]
 dd[7,4] <- d[7] - d[4] + wf[2]
 or73 <- exp(dd[7,3])
 or74 <- exp(dd[7,4])

 d[1] <- 0
 for (k in 2:NT) {
  dd[k,1] <- d[k]
  d[k] ∼ dnorm(0, 0.0001)
  ed[k] <- exp(d[k]) # ed is odds ratio against placebo
 }
 for (i in 1:2) {
  wf[i] ∼ dnorm(0, tau.w)
 }

 sd∼dunif(0.01,2)
 tau <- 1/pow(sd,2)
 var <- pow(sd,2)

 sd.w ∼ dunif(0.01,2)
 var.w <- pow(sd.w, 2)
 tau.w <- 1/var.w

 IP <- step(var.w-var)
 # pairwise ORs
 # Example: or[2,3] = odds ratio of active(2) vs. control(3)
 for (k in 1:NT) {
  for (c in 1:NT) {
   lor[k,c] <- d[k] - d[c]
   log(or[k,c]) <- lor[k,c]
  }
 }

 # ranking
 mP <- mean(mu[1:27])     # Take average of mu[]

 for (k in 1:NT) { logit(T[k]) <- mP + d[k] }
 for (k in 1:NT) {
  rk[k] <- NT + 1 - rank(T[],k)
  best1[k] <- equals(rk[k],1)
  best2[k] <- equals(rk[k],2)
  best12[k] <- best1[k] + best2[k]
 }
}

#Init
list(
d=c(NA,0,0,0,0,0,0,0),
sd=1,
sd.w=1,
mu=c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0)
)

#Data are the same as in Model 2

#SAS code for frequntist analysis with respect to the UI improvement outcome

/* Numbering of drugs are different from in the WinBUGS code */
/* since SAS consider the largest number as reference group */
/* 1=trospium; 2=tolterodine; 3=solifenacin; 4=propiverine; */
/* 5=oxybutynin; 6=fesoterodine; 7=darifenacin; 8=placebo */

data UI_imp;
input Study trt r n Narm Index Revindex Notfirst NotLast;
datalines;
1   2   256   684   3   1   3   0   1
1   6   293   679   3   2   2   1   1
1   8   113   334   3   3   1   1   0
2   2   79    690   3   1   3   0   1
2   6   102   685   3   2   2   1   1
2   8   32    337   3   3   1   1   0
…
;
run;

/* Fixed effects model */
proc genmod data=UI_imp;
class study trt;
model R/N = Study trt /link=logit dist=bin ;
lsmeans trt /diff cl;
run;

/* Random effects model */
data UI_imp2;
set UI_imp;
array x[3] x1-x3;
do i=1 to 3;
        if i<= narm then x[i]=sqrt(0.5)*((i=index)-1/narm);
        else x[i]=0;
end;
run;

proc glimmix data=UI_imp2 method=QUAD;
class study Trt ;
model R/N = Trt Study/link=logit dist=bin ddfm=none;
random X1 X2 X3/ subject=study type=TOEP(1) ;
lsmeans Trt /diff cl oddsratios;
run;