# Summary of Bayesian Models Under the Noninformative Prior

Fixed effect model | Random effect model (homogeneous) | Random effect model (heterogeneous) | Random effect model (inconsistency)
[underlined: Data]; r_ik_ ∼ Bin(n_ik_, p_ik_); i = 1, …, NS; k = 1, …, NT (NS = number of study; NT = number of trt) [underlined: Model]; logit(p_ik_) = μ_iB_ + Δ_Bk_; where B is for the baseline treatment, μ_iB_ is the log odds of the baseline treatment and Δ_Bk_ is the fixed effect of the k^th^ drug versus the baseline treatment defined by d_k_ − d_B_ with the fixed effect of the k^th^ drug versus placebo, d_k_ (d_B_ = 0) [underlined: Prior]; d_k_ ∼ N(0, 10000) μ_iB_ ∼ N(0, 10000) | [underlined: Data]; r_ik_ ∼ Bin(n_ik_, p_ik_); [underlined: Model]; logit(p_ik_) = μ_iB_ + δ_iBk_; where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior]; δ_iBk_ ∼ N(d_k_ – d_B_, σ^2^) d_k_ ∼ N(0, 10000) μ_iB_ ∼ N(0, 10000) σ ∼Unif(0.01,2) | [underlined: Data]; r_ik_ ∼ Bin(n_ik_, p_ik_); [underlined: Model]; logit(p_ik_) = μ_iB_ + δ_iBk_; where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior]; δ_iBk_ ∼ N(d_k_ – d_B_, σ_Bk_^2^) d_k_ ∼ N(0, 10000) μ_iB_ ∼ N(0, 10000) logσ_xy_ = logσ_0_ + ν_xy_ σ_0_ ∼Unif(0.01,2) ν_xy_ ∼ N(0, ψ^2^) | [underlined: Data]; r_ik_ ∼ Bin(n_ik_, p_ik_); [underlined: Model]; logit(p_ik_) = μ_iB_ + δ_iBk_; where δ_ik_ is the random effect of of the k^th^ drug versus the placebo in the i^th^ study; 1. d_BC_ = d_AC_ – d_AB_ + w_ABC_; w_ABC_ is the amount of inconsistency between direct and indirect comparisons [underlined: Prior]; δ_iBk_ ∼ N(d_k_ – d_B_, σ^2^) d_k_ ∼ N(0, 10000) μ_iB_ ∼ N(0, 10000) w_ABC_ ∼ N(0, σ_w_^2^) σ, σ_w_ ∼Unif(0.01,2)
[Example] Study 1: Drugs 1 vs. 2 vs. 3 trial (drug 1 is the baseline treatment)
Fixed effect model | Random effect model (homogeneous) | Random effect model (heterogeneous) | Random effect model (inconsistency)
[underlined: Data]; r_11_ ∼ Bin(n_11_, p_11_) r_12_ ∼ Bin(n_12_, p_12_) r_13_ ∼ Bin(n_13_, p_13_); [underlined: Model]; 2 logit(p_11_) = μ_11_; 3 logit(p_12_) = μ_11_+ d_2_; 4 logit(p_13_) = μ_11_+ d_3_; [underlined: Prior]; d_2_, d_3_ ∼ N(0, 10000) μ_11_ ∼ N(0, 10000) | [underlined: Model]; 5 logit(p_11_) = μ_11_; 6 logit(p_12_) = μ_11_ + δ_12_; 7 logit(p_13_) = μ_11_ + δ_13_; [underlined: Prior (assume ρ=0.5)]; ( δ_12_ δ_13_ ) ∼ MVN ( d_2_ d_3_ ) , σ^3^ ( 1 0.5 0.5 1 ) ); → δ_12_ ∼ N (d_2_, σ^2^); → δ_13_ ∣ δ_12_ ∼ N ( d_3_ + (1)/(2) ( δ_12_ − d_2_ ) , (3)/(4) σ^2^ ); d_2_, d_3_ ∼ N(0, 10000) μ_11_ ∼ N(0, 10000) σ ∼Unif(0.01,2) | [underlined: Model]; 8 logit(p_11_) = μ_11_; 9 logit(p_12_) = μ_11_ + δ_12_; 10 logit(p_13_) = μ_11_ + δ_13_; [underlined: Prior (assume ρ=0.5)]; ( δ_12_ δ_13_ ) ∼ MVN ( d_2_ d_3_ ) , ( σ_11_^2^ 0.5 σ_12_ 0.5 σ_12_ σ_22_^2^ ) ); → δ_12_ ∼ N ( d_2_ , σ_1_^2^ ); → δ_13_ ∣ δ_12_ ∼ N ( d_3_ + (1)/(2) ( δ_12_ − d_2_ ) , (3)/(4) σ_2_^2^ ); d_2_, d_3_ ∼ N(0, 10000) μ_11_ ∼ N(0, 10000) logσ_11_ = logσ_0_ + ν_11_ logσ_12_ = logσ_0_ + ν_12_ logσ_22_ = logσ_0_ + ν_22_ σ_0_ ∼ Unif(0.01,2) ν_11_, ν_12_, ν_22_ ∼ Unif(0.01, ψ^2^) | Study 1: 1 vs. 2 vs. 3 trial; 11 Study 2: 1 vs. 2; 12 Study 3: 1 vs. 3; → We can estimate w_123_ because the data permit estimation via the equation; d_23_ = d_13_ − d_13_ + w_123_; Model and priors are similarly defined as in Model2. Additional prior is; w_123_ ∼ N(0, σ_w_^2^) σ_w_ ∼ Unif(0.01,2)