# Abbreviations

AE: Adverse effect
AIC: Akaike information criterion
ARD: Absolute risk difference
DIC: Deviance information criterion
FDA: Food and Drug Administration
MCMC: Markov chain Monte Carlo
MTC: Mixed (or multiple) treatment comparison
NNT: Number needed to treat
OAB: Overactive bladder
RCT: Randomized controlled trial
UI: Urinary incontinence