# Summary

Systematic reviewers routinely prioritize evidence in numerous ways. Our goal in this paper has been to provide a framework for understanding the possibilities, considering influential factors, and choosing among the myriad of options. This will help enhance the transparency of review processes, which in turn may help users determine how different reviews of the same topic can reach different conclusions.