# References

1 Slavin RE. Best evidence synthesis: an intelligent alternative to meta-analysis. J Clin Epidemiol. Jan. 1995;48(1):9-18. [pmid: 7853053].
2 Agency for Healthcare Research and Quality. Guide for conducting comparative effectiveness reviews. [draft for public comment]. Chapter 3, Selecting evidence: controlled trials. Rockville (MD). Agency for Healthcare Research and Quality. 2007.
3 Norris S, Atkins D, Bruening W, et al. Observational studies in systematic reviews of comparative effectiveness. J Clin Epidemiol. in press. 1-25.
4 Dundar Y, Hill R, Dickson R, et al. Comparative efficacy of thrombolytics in acute myocardial infarction: a systematic review. QJM. Feb. 2003;96(2):103-13. [pmid: 12589008].
5 Schmieder RE, Martus P, Klingbeil A. Reversal of left ventricular hypertrophy in essential hypertension. A meta-analysis of randomized double-blind studies. JAMA. May. 15. 1996;275(19):1507-13. [pmid: 8622227].
6 Porzio F. Meta-analysis of three double-blind comparative trials with sustained-release etodolac in the treatment of osteoarthritis of the knee. Rheumatol Int. 1993;13(2 Suppl):S19-24. [pmid: 8210920].
7 Lipton A, Stopeck A, van Moos R, et al. A meta-analysis of results from two randomized, double-blind studies of denosumab versus zoledronic acid (ZA) for treatment of bone metastases. J Clin Oncol. 2010;28(15 Suppl):9015.
8 Ostermann T, Raak C, Bussing A. Survival of cancer patients treated with mistletoe extract (Iscador): a systematic literature review. BMC Cancer. 2009;9:451. [pmid: 20021637].
9 Abbas S, Seitz M. Systematic review and meta-analysis of the used surgical techniques to reduce leg lymphedema following radical inguinal nodes dissection. Surg Oncol. 2009. Dec. 9. [pmid: 20005090].
10 Ziegler R, Grossarth-Maticek R. Individual patient data meta-analysis of survival and psychosomatic self-regulation from published prospective controlled cohort studies for long-term therapy of breast cancer patients with a mistletoe preparation (Iscador). Evid Based Complement Alternat Med. 2008 Apr 11 (Epub). [pmid: 18955332].
11 Morshed S, Bozic KJ, Ries MD, et al. Comparison of cemented and uncemented fixation in total hip replacement: a meta-analysis. Acta Orthop. Jun. 2007;78(3):315-26. [pmid: 17611843].
12 Abraham NS, Byrne CM, Young JM, et al. Meta-analysis of non-randomized comparative studies of the short-term outcomes of laparoscopic resection for colorectal cancer. ANZ J Surg. Jul. 2007;77(7):508-16. [pmid: 17610681].
13 Higgins JP, Green S, editors. Cochrane handbook for systematic reviews of interventions 5.0.2. The Cochrane Collaboration. 2008. [updated 2009 Sep 1]. Available at: http://www.cochrane-handbook.org/.
14 Cook DJ, Sackett DL, Spitzer WO. Methodologic guidelines for systematic reviews of randomized control trials in health care from the Potsdam Consultation on Meta-Analysis. J Clin Epidemiol. Jan. 1995;48(1):167-71. [pmid: 7853043].
15 Egger M, Smith GD, Phillips AN. Meta-analysis. Principles and procedures. BMJ. Dec. 6. 1997;315(7121):1533-7. [pmid: 9432252].
16 Sutton AJ, Abrams KR, Jones DR, et al. Methods for meta-analysis in medical research Sensitivity analysis. London. John Wiley. Wiley series in probability and statistics: applied probability and statistics. 2000:147-52.
17 Egger M, Smith GD. Principles of and procedures for systematic reviews. Egger M, Smith GD, Altman DG, editors. Systematic reviews in health care: meta-analysis in context. 2nd. London. BMJ Books. 2001:23-42.
18 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions 4.2.6. The Cochrane Collaboration. 2006. [updated 2006 Sep 1]. Available at: http://www.cochrane.org/sites/default/files/uploads/Handbook4.2.6Sep2006.pdf.