# Peer Reviewers

Laura J. Fochtmann, M.D.

Professor of Psychiatry and Behavioral Sciences

Stony Brook University School of Medicine

Stony Brook, NY

Susan Norris, M.D., M.Sc., M.P.H.

Assistant Professor, Department of Medical Informatics and Clinical Epidemiology

Oregon Evidence-based Practice Center

Oregon Health & Science University

Portland, OR

Diana Pettiti, M.D., M.P.H.

Professor, Biomedical Informatics

Arizona State University

Phoenix, AZ