# Acknowledgments

The research team would like to acknowledge the efforts of Eileen Erinoff, M.S.L.I.S., and Helen Dunn for providing literature retrieval and documentation management support; and Janice Kaczmarek, M.S., Gina Giradi, M.S., and Kitty Donahue for program management, editorial support, and administrative support.