# Tabulation of Inclusion Criteria and Modifying Factors

Table A1 Criteria related to study design and modifying factors

| Number of Studies (for Each Relevant Outcome) | Disease Course | Outcome Subjectivity (can Knowledge of Intervention Group Affect Outcome) | Potential for Unmeasured Confounders | Degree of Relevance | Frequency of Outcome Occurrence | Feasibility | Ethical Considerations | Minimum Time Needed to Evaluate Intervention Effect | Is outcome a Harm of intervention? | Concomitant Interventions or Processes of Care Changed Over Time | Possibility of Substantial Carryover Effect if Interventions Given Sequentially | Will Meta-analysis be Performed? | Degree of Similarity Among Different Studies (Participants, Interventions) | Degree of Similarity Among Patients who did and did not Provide Data
Random assignment to intervention groups | ✓ | | | ✓ | ✓ | | | ✓ | | ✓
Blinding of study participants to which intervention they received | ✓ | | ✓ | | ✓ | | ✓ | ✓ | | ✓
Blinding of providers to the intervention that they provided | ✓ | | ✓ | | ✓ | | ✓ | | | ✓
Blinding of outcome assessors to the assigned intervention | ✓ | | ✓ | | ✓ | | ✓ | | | ✓
Presence of independent comparison group | ✓ | ✓ | | | | | | | | ✓ | | ✓
Presence of concurrent comparison group | ✓ | ✓ | | | | | | | | | ✓
Presence of a before-after comparison | ✓ | ✓ | | | | | | | | ✓ | ✓ | ✓
Adequate washout period | ✓ | | | | | | | | | | | ✓
The intervention comparison must be direct, not indirect | ✓ | | | | | | | | | | | | | ✓
Good baseline comparability | ✓
Prospective planning (the study question was determined before any data were collected) | ✓
Consecutive enrollment | ✓

Table A2 Criteria pertaining to study conduct and reporting, and modifying factors

| Number of Studies (for Each Relevant Outcome) | Disease Course | Outcome Subjectivity (can Knowledge of Intervention Group Affect Outcome) | Potential for Unmeasured Confounders | Degree of Relevance | Frequency of Outcome Occurrence | Feasibility | Ethical Considerations | Minimum Time Needed to Evaluate Intervention Effect | Is outcome a Harm of intervention? | Concomitant Interventions or Processes of Care Changed Over Time | Possibility of Substantial Carryover Effect if Interventions Given Sequentially | Will Meta-analysis be Performed? | Degree of Similarity Among Different Studies (Participants, Interventions) | Degree of Similarity Among Patients who did and did not Provide Data
The minimum length of followup was x | ✓ | ✓ | | | | | | | ✓
The minimum number of study participants per group who provided data was x | ✓ | | | | | ✓
The minimum % of enrollees who provided data was x% | ✓ | | | | | | | | | | | | | | ✓
Percent difference between groups in proportion of study participants who had usable data (only studies with comparison groups) | ✓
Calculable or imputable effect size | ✓ | | | | | | | | | | | | ✓
Study must have used validated method of outcome measurement measuring instruments | ✓

Table A3 Criteria pertaining to relevance and modifying factors

| Number of Studies (for Each Relevant Outcome) | Disease Course | Outcome Subjectivity (can Knowledge of Intervention Group Affect Outcome) | Potential for Unmeasured Confounders | Degree of Relevance | Frequency of Outcome Occurrence | Feasibility | Ethical Considerations | Minimum Time Needed to Evaluate Intervention Effect | Is outcome a Harm of intervention? | Concomitant Interventions or Processes of Care Changed Over Time | Possibility of Substantial Carryover Effect if Interventions Given Sequentially | Will Meta-analysis be Performed? | Degree of Similarity Among Different Studies (Participants, Interventions) | Degree of Similarity Among Patients who did and did not Provide Data
Study participant characteristics are sufficiently similar to the participants specified in the Key Question (e.g., adults vs. children) | ✓
Interventions (both treatment and comparator) sufficiently similar to the interventions specified in the Key Question | ✓
Setting characteristics are sufficiently similar to the setting specified in the Key Question (e.g., inpatient vs. outpatient) | ✓