# Appendixes

Appendix A Tabulation of Inclusion Criteria and Modifying Factors