# References

1 Bennett WL, Wilson LM, Bolen S, et al. Oral diabetes medications for adults with type 2 diabetes: an update. Comparative Effectiveness Review No. 27. AHRQ Publication No. 11-EHC038-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Matchar DB, McCrory DC, Orlando LA, et al. Comparative effectiveness of angiotensin-converting enzyme inhibitors (ACEIs) and angiotensin ii receptor antagonists (ARBs) for treating essential hypertension [Internet]. Comparative Effectiveness Review No. 10. AHRQ Publication No. 08-EHC003-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2007.
3 Bravata DM, McDonald KM, Gienger AL, et al. Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease. AHRQ Publication No. 08-EHC002-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2007.
4 Coleman CI, Baker WL, Kluger J, et al. Comparative effectiveness of angiotensin converting enzyme inhibitors or angiotensin II receptor blockers added to standard medical therapy for treating stable ischemic heart disease. Comparative Effectiveness Reviews No. 18. AHRQ Publication No. 10-EHC002-EF 2009. Rockville, MD. Agency for Healthcare Research and Quality. October. 2009.
5 Bolen S, Wilson L, Vassy J, et al. Comparative Effectiveness and Safety of Oral Diabetes Medications for Adults With Type 2 Diabetes. Comparative Effectiveness Reviews No. 8. AHRQ Publication No. 07-EHC010-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2007. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
6 Hochman M, McCormick D. Characteristics of published comparative effectiveness studies of medications. JAMA. 2010;303(10):951-8. [pmid: 20215609].
7 Froberg DG, Kane RL. Methodology for measuring health-state preferences--I: measurement strategies. J Clin Epidemiol. 1989;42(4):345-54. [pmid: 2723695].
8 Institute of Medicine. Finding What Works in Health Care: Standards for Systematic Reviews. Eden J, Levit L, Berg A, et al., editors. Washington, DC. National Academies Press. 2011.
9 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011. Chapters available at: www.effectivehealthcare.ahrq.gov.
10 Nissen SE, Wolski K. Effect of rosiglitazone on the risk of myocardial infarction and death from cardiovascular causes. N Engl J Med. 2007;356(24):2457-71. [pmid: 17517853].
11 Bangalore S, Kumar S, Messerli FH. Angiotensin-converting enzyme inhibitor associated cough: deceptive information from the Physicians' Desk Reference. Am J Med. 2010;123(11):1016-30. [pmid: 21035591].
12 Bennett WL, Maruthur NM, Singh S, et al. Comparative effectiveness and safety of medications for type 2 diabetes: an update including new drugs and 2-drug combinations. Ann Intern Med. 2011;154(9):602-13. [pmid: 21403054].
13 Guo JJ, Pandey S, Doyle J, et al. A review of quantitative risk-benefit methodologies for assessing drug safety and efficacy-report of the ISPOR risk-benefit management working group. Value Health. 2010;13(5):657-66. [pmid: 20412543].
14 Gail MH, Costantino JP, Bryant J, et al. Weighing the risks and benefits of tamoxifen treatment for preventing breast cancer. J Natl Cancer Inst. 1999;91(21):1829-46. [pmid: 10547390].
15 European Medicines Agency. Report of the Committee for Medicinal Products Working Group on Benefit-Risk Assessment Models and Methods. EMEA/CHMP/15404/2007. 2007. Available at: http://www.ema.europa.eu/docs/en_GB/documen_library/Regulatory_and_procedural_guideline/2010/01/WC500069668.pdf. October 21, 2012.
16 O'Neill RT. A perspective on characterizing benefits and risks derived from clinical trials: can we do more?. Drug Information Journal. 2008;42(3):235-45.
17 Hughes DA, Bayoumi AM, Pirmohamed M. Current assessment of risk-benefit by regulators: is it time to introduce decision analyses?. Clin Pharmacol Ther. 2007;82(2):123-7. [pmid: 17632534].
18 Psaty BM, Furberg CD. COX-2 inhibitors--lessons in drug safety. N Engl J Med. 2005;352:1133-5. [pmid: 15713946].
19 Caroll C, Patterson M, Wood S, et al. A conceptual framework for implementation fidelity. Implement Sci. 2007;30(2):40.
20 Dane AV, Schneider BH. Program integrity in primary early and secondary prevention. Are implementation effects out of control?. Clin Psychol Rev. Jan. 1998;18(1):23-45. [pmid: 9455622].
21 Helfand M, Balshem H. AHRQ Series Paper 2: Principles for developing guidance: AHRQ and the effective health-care program. J Clin Epidemiol. 2010. 2010;63:484-90. [pmid: 19716268].
22 Ferreira-Gonzalez I, Busse JW, Heels-Ansdell D, et al. Problems with use of composite end points in cardiovascular trials: systematic review of randomised controlled trials. BMJ. 2007;334(7597):786. [pmid: 17403713].
23 Institute of Medicine Committee on Qualification of Biomarkers and Surrogate Endpoints in Chronic Disease. Evaluation of Biomarkers and Surrogate Endpoints in Chronic Disease. Micheel CM, Ball JR, editors. Washington, DC. The National Academies Press. 2010.
24 Hulley S, Grady D, Bush T, for the Heart and Estrogen/progestin Replacement Study (HERS) Research Group. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. JAMA. 1998;280:605-13. [pmid: 9718051].
25 Chou R, Aronson N, Atkins D, et al. AHRQ Series Paper 4: Assessing Harms When Comparing Medical Interventions: AHRQ and the Effective Health-care Program. J Clin Epidemiol. 2010;63(5):502-12. [pmid: 18823754].
26 Guyatt GH, Oxman AD, Vist GE, et al. GRADE: An Emerging Consensus on Rating Quality of Evidence and Strength of Recommendations. BMJ. 2008;336(7650):924-6. [pmid: 18436948].
27 Sin DD, Tashkin D, Zhang X, et al. Budesonide and the risk of pneumonia: a meta-analysis of individual patient data. Lancet. 2009;374(9691):712-9. [pmid: 19716963].
28 Greenland S. Additive Risk versus Additive Relative Risk Models. Epidemiology. 1993;4:32-6. [pmid: 8420578].
29 Akl EA, Oxman AD, Herrin J, et al. Using alternative statistical formats for presenting risks and risk reductions. Cochrane Database of Systematic Reviews. 2011;(3):CD006776.
30 American Academy of Orthopedic Surgeons. Clinical Guideline on Prevention of Pulmonary Embolism in Patients Undergoing Total Hip or Knee Arthroplasty. [Web Page]. May. 2007. Available at http://www.aaos.org/research/guidelines/pe_guideline.pdf.
31 Geerts WH, Bergqvist D, Pineo GF, et al. American College of Chest Physicians. Prevention of venous thromboembolism: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines (8th Edition). Chest. 2008;133(6 Suppl):381S-453S. [pmid: 18574271].
32 Lacasse Y, Goldstein R, Lasserson TJ, et al. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2006;(4):CD003793. [pmid: 17054186].
33 Singer DE, Albers GW, Dalen JE, et al. Antithrombotic therapy in atrial fibrillation: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines (8th Edition). Chest. 2008;133(6 Suppl):546S-92S. [pmid: 18574273].
34 Dolan JG. Multi-criteria Clinical Decision Support: A Primer on the Use of Multiple Criteria Decision Making Methods to Promote Evidence-based, Patient-centered Healthcare. Patient. 2010;3(4):229-48. [pmid: 21394218].
35 Singh S, Dolan JG, Centor RM. Optimal management of adults with pharyngitis--a multi-criteria decision analysis. BMC Med Inform Decis Mak. 2006;6:14. [pmid: 16533386].
36 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for the prevention of breast cancer: current status of the National Surgical Adjuvant Breast and Bowel Project P-1 study. J Natl Cancer Inst. 2005;97(22):1652-62. [pmid: 16288118].
37 Shakespeare TP, Gebski VJ, Veness MJ, et al. Improving interpretation of clinical studies by use of confidence levels, clinical significance curves, and risk-benefit contours. Lancet. 2001;357(9265):1349-53. [pmid: 11343760].
38 Chong J, Poole P, Leung B, et al. Phosphodiesterase 4 inhibitors for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2011;(5):CD002309. [doi: 10.1002/14651858.CD002309.pub3].
39 Aspirin for the prevention of cardiovascular disease: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;150(6):396-404. [pmid: 19293072].
40 Chuang-Stein C. A new proposal for benefit-less-risk analysis in clinical trials. Control Clin Trials. 1994;15(1):30-43. [pmid: 7908619].
41 Boers M, Brooks P, Fries JF, et al. A first step to assess harm and benefit in clinical trials in one scale. J Clin Epidemiol. 2010;63(6):627-32. [pmid: 19800197].
42 Ponce RA, Bartell SM, Wong EY, et al. Use of quality-adjusted life year weights with dose-response models for public health decisions: a case study of the risks and benefits of fish consumption. Risk Anal. 2000;20(4):529-42. [pmid: 11051076].
43 Garrison LP Jr, Towse A, Bresnahan BW. Assessing a structured, quantitative health outcomes approach to drug risk-benefit analysis. Health Aff (Millwood). May-Jun. 2007;26(3):684-95. [pmid: 17485745].
44 Mussen F, Salek S, Walker S. A quantitative approach to benefit-risk assessment of medicines - part 1: the development of a new model using multi-criteria decision analysis. Pharmacoepidemiol Drug Saf. Suppl 1. 2007;16:S2-S15. [pmid: 17546573].
45 Mussen F, Salek S, Walker S, et al. A quantitative approach to benefit-risk assessment of medicines - part 2: the practical application of a new model. Pharmacoepidemiol Drug Saf. Suppl 1. 2007;16:S16-41. [pmid: 17546574].
46 Holden WL, Juhaeri J, Dai W. Benefit-risk analysis: a proposal using quantitative methods. Pharmacoepidemiol Drug Saf. 2003;12(7):611-6. [pmid: 14558185].
47 Dolan JG. Shared decision-making--transferring research into practice: the analytic hierarchy process (AHP). Patient Educ Couns. 2008;73(3):418-25. [pmid: 18760559].
48 Holden WL, Juhaeri J, Dai W. Benefit-risk analysis: examples using quantitative methods. Pharmacoepidemiol Drug Saf. 2003;12(8):693-7. [pmid: 14762986].
49 Sutton AJ, Cooper N, Abrams KR, et al. A Bayesian approach to evaluating net clinical benefit allowed for parameter uncertainty. J Clin Epidemiol. 2005;58(1):26-40. [pmid: 15649668].
50 Laupacis A, Sackett DL, Roberts RS. An assessment of clinically useful measures of the consequences of treatment. N Engl J Med. 1988;318(26):1728-33. [pmid: 3374545].
51 Cook RJ, Sackett DL. The number needed to treat: a clinically useful measure of treatment effect. BMJ. 1995;310(6977):452-4. [pmid: 7873954].
52 Osiri M, Suarez-Almazor ME, Wells GA, et al. Number needed to treat (NNT): implication in rheumatology clinical practice. Ann Rheum Dis. 2003;62(4):316-21. [pmid: 12634229].
53 Walter SD, Sinclair JC. Uncertainty in the minimum event risk to justify treatment was evaluated. J Clin Epidemiol. 2009;62(8):816-24. [pmid: 19216053].
54 Lynd LD, Najafzadeh M, Colley L, et al. Using the incremental net benefit framework for quantitative benefit-risk analysis in regulatory decision-making—a case study of alosetron in irritable bowel syndrome. Value Health. 2010;13(4):411-7. [pmid: 19744297].
55 Shaffer ML, Watterberg KL. Joint distribution approaches to simultaneously quantifying benefit and risk. BMC Med Res Methodol. 2006;6:48. [pmid: 17038184].
56 Lynd LD, O'brien BJ. Advances in risk-benefit evaluation using probabilistic simulation methods: an application to the prophylaxis of deep vein thrombosis. J Clin Epidemiol. 2004;57(8):795-803. [pmid: 15485731].
57 Gelber RD, Goldhirsch A, Cole BF. Evaluation of effectiveness: Q-TWiST. The International Breast Cancer Study Group. Cancer Treat Rev. Suppl A. 1993;19:73-84. [pmid: 7679323].
58 Gelber RD, Goldhirsch A, Cole BF, et al. A quality-adjusted time without symptoms or toxicity (Q-TWiST) analysis of adjuvant radiation therapy and chemotherapy for resectable rectal cancer. J Natl Cancer Inst. 1996;88(15):1039-45. [pmid: 8683634].
59 Sherrill B, Amonkar MM, Stein S, et al. Q-TWiST analysis of lapatinib combined with capecitabine for the treatment of metastatic breast cancer. Br J Cancer. 2008;99(5):711-5. [pmid: 18728660].
60 Ryan M, McIntosh E, Shackley P. Methodological issues in the application of conjoint analysis in health care. Health Econ. 1998;7(4):373-8. [pmid: 9683097].
61 Johnson FR, Ozdemir S, Mansfield C, et al. Are adult patients more tolerant of treatment risks than parents of juvenile patients?. Risk Anal. 2009;29(1):121-36. [pmid: 18826414].
62 Hauber AB, Mohamed AF, Johnson FR, et al. Treatment preferences and medication adherence of people with Type 2 diabetes using oral glucose-lowering agents. Diabet Med. 2009;26(4):416-24. [pmid: 19388973].
63 Johnson FR, Van Houtven G, Ozdemir S, et al. Multiple sclerosis patients' benefit-risk preferences: serious adverse event risks versus treatment efficacy. J Neurol. 2009;256(4):554-62. [pmid: 19444531].
64 Bachmann LM, Muhleisen A, Bock A, et al. Vignette studies of medical choice and judgment to study caregivers' medical decision behaviour: systematic review. BMC Med Res Methodol. 2008;8:50. [pmid: 18664302].
65 Johnson FR, Ozdemir S, Mansfield C, et al. Crohn's disease patients' risk-benefit preferences: serious adverse event risks versus treatment efficacy. Gastroenterology. 2007;133(3):769-79. [pmid: 17628557].
66 Tugwell P, Boers M, Strand V, et al. OMERACT 9 - 9th International Consensus Conference on outcome measures in rheumatology clinical trials. J Rheumatol. 2009;36(8):1765-8. [pmid: 19671811].
67 Golder S, Loke YK, Bland M. Meta-analyses of adverse effects data derived from randomised controlled trials as compared to observational studies: methodological overview. PLoS Med. 2011;8(5):e1001026. [pmid: 21559325].
68 Levitan B. A concise display of multiple end points for benefit-risk assessment. Clin Pharmacol Ther. 2011;89(1):56-9. [pmid: 21107317].
69 Sackett DL, Richardson WS, Rosenberg W, et al. Evidence-based medicine. How to practice and teach EBM. Churchill Livingstone. Edinburgh. 1997.
70 JAMA Evidence Glossary. [Web Page]. Available at http://jamaevidence.com/glossary/V. October 21, 2012.
71 Krahn M, Naglie G. The next step in guideline development: incorporating patient preferences. JAMA. 2008;300(4):436-8. [pmid: 18647988].
72 Institute of Medicine. Committee on Conflict of Interest in Medical Research, Education, and Practice. Lo B, Field MJ, editors. Conflict of interest in medical research, education, and practice. Washington, DC. National Academies Press. 2009.
73 Guyatt G, Cook D, Haynes B. Evidence based medicine has come a long way. BMJ. 2004;329(7473):990-1. [pmid: 15514320].
74 Guyatt G, Montori V, Devereaux PJ, et al. Patients at the centre: in our practice, and in our use of language. Evid Based Med. 2004;9(1):6-7.
75 D'Agostino RBJ. Debate: the slippery slope of surrogate outcomes. Curr Control Trials Cardiovasc Med. 2000;1(2):76-8. [pmid: 11714414].
76 Singh S, Loke YK, Furberg CD. Long-term risk of cardiovascular events with rosiglitazone: a meta-analysis. JAMA. 2007;298(10):1189-95. [pmid: 17848653].
77 Loke YK, Price D, Herxheimer A. Systematic reviews of adverse effects: framework for a structured approach. BMC Med Res Methodol. 2007;7:32. [pmid: 17615054].
78 Butler M, Tally KMC, Burns R, et al. Values of Older Adults Related to Primary and Secondary Prevention. Evidence Synthesis No. 84. AHRQ Publication No. 11-05154-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011.
79 Guyatt GH, Oxman AD, Kunz R, et al. Going from evidence to recommendations. BMJ. 2008;336(7652):1049-51. [pmid: 18467413].
80 U.S. Preventive Services Task Force. Methods and Processes. Available at: http://www.uspreventiveservicestaskforce.org/methods.htm. October 21, 2012.
81 Guyatt G, Akl EA, Hirsh J, et al. The vexing problem of guidelines and conflict of interest: a potential solution. Ann Intern Med. 2010;152(11):738-41. [pmid: 20479011].
82 Shamliyan T, Wyman JF, Ramakrishnan R, et al. Benefits and harms of pharmacologic treatment for urinary incontinence in womena systematic review. Ann Intern Med. Jun. 2012;156(12):861-874. Available at: http://www.annals.org/content/early/2012/04/09/0003-4819-156-12-201206190-00436.full#fn-group-1. October 21, 2012. [pmid: 22711079].
83 Protheroe J, Fahey T, Montgomery AA, et al. Effects of patients' preferences on the treatment of atrial fibrillation: observational study of patient-based decision analysis. West J Med. 2001;174(5):311-5. [pmid: 11342503].
84 Akl EA, Schunemann HJ, Grant B, et al. Working-group for evidence based decision making (WEB Decision Making). Making decisions about using inhaled steroids in COPD. Available at: http://www.predictonline.com/copd/smbs/spm_copd/. October 21, 2012.
85 Wennberg JE. Tracking medicine: a researcher's quest to understand health care. New York. Oxford University Press. 2010.
86 Fisher ES, Wennberg JE. Health care quality, geographic variations, and the challenge of supply-sensitive care. Perspect Biol Med. 2003;46(1):69-79. [pmid: 12582271].
87 Sussman JB, Vijan S, Choi H, et al. Individual and population benefits of daily aspirin therapy: a proposal for personalizing national guidelines. Circ Cardiovasc Qual Outcomes. 2011;4(3):268-75. [pmid: 21487091].
88 Politi MC, Han PK, Col NF. Communicating the uncertainty of harms and benefits of medical interventions. Med Decis Making. 2007;27(5):681-95. [pmid: 17873256].
89 Montori VM, Permanyer-Miralda G, Ferreira-Gonzalez I, et al. Validity of composite end points in clinical trials. BMJ. 2005;330(7491):594-6. [pmid: 15761002].
90 Song F, Loke Y, Walsh T, et al. Methodological problems in the use of indirect comparisons for evaluating healthcare interventions: survey of published systematic reviews. BMJ. 2009;338:b1147. [pmid: 19346285].