# Principles for Assessing Benefit and Harm in Systematic Reviews

## Systematic Review Protocol Development

### Identify the Key Potential Benefits and Harms

Systematic reviews should attempt to inform the harm and benefit assessment by identifying the key benefits and harms, including the health outcomes most important to patients, in the analytic framework. The Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Comparative Effectiveness Reviews lists this as standard guidance for systematic reviews.9 Systematic reviewers should carefully consider how they will combine the effects of treatments on multiple benefits and harms as well as how they will incorporate patient preferences for these different outcomes.

When data on important health outcomes are unavailable, reviewers should report on the way in which treatments affect potential surrogate outcomes and assess the strength of the linkage between surrogate measures and either benefits or harms. In circumstances where only benefits on potential surrogate outcomes are available and their linkages to health outcomes are not validated, reviewers should discuss with end users the potential value of a benefit harm assessment on surrogate outcomes.

### Report the Characteristics and Assumptions of the Selected Quantitative Approaches

The various quantitative approaches differ in key characteristics. While most quantitative approaches for benefit harm assessment are feasible whether using aggregate or individual patient data, some methods (e.g., benefit-less-risk analysis) specifically require individual patient data. Some are typically based on RCTs only (e.g., number-needed-to-treat to number-needed- to harm ratio (ratio of NNT over NNH), while others can consider both experimental and observational data (e.g., probabilistic simulation modeling, Gail/NCI (National Cancer Institute) approach, or multi criteria decision analysis).

Another key characteristic of a quantitative approach for benefit harm assessment is the number and diversity of benefit and harm outcomes that it incorporates. While some approaches typically focus on a single or a few outcomes of similar severity (e.g., NNT/NNH ratio or transparent uniform risk benefit overview), others incorporate a potentially large number of outcomes of different importance (e.g., Gail/NCI approach or multi criteria decision analysis). Since little empirical data exist to suggest that one particular quantitative approach for assessing benefits and harms is superior to another, systematic reviewers should consider which quantitative approach is most appropriate for the decisionmaking context, the data available through the systematic review, and the methodological expertise of the review team. If the reviewers decide for or against a particular approach to quantitative assessment of benefit and harm balance, they should report the rationale for this decision. They should also describe the characteristics and assumptions of the selected quantitative approach.

### State Whether Preferences Were Considered in the Benefit Harm Assessment, and If So, Describe How These Were Ascertained and How Variation in Preferences Would Affect the Assessment

Preferences affect the assessment of benefits and harms in any review of evidence. In current practice, these preferences are often implicit and those conducting an assessment of benefits and harms do not necessarily recognize and transparently report them. This is true whether a review simply reports on benefits and harms, or whether quantitative approaches are used to provide a benefit and harm comparison estimate.

Systematic reviews should explain and justify the rationale for their choice of various study designs or various outcomes that inform the assessment of benefits and harms and any other steps in the process of evidence synthesis where preferences play a role. They should consider performing systematic searches for studies on patient preferences for relevant outcomes and conducting sensitivity analyses to determine the impact of varying preferences on assessing benefit and harm.

### Describe Whether Systematic Reviewers Use a Qualitative Assessment or a Quantitative Approach for Benefit Harm Assessment

Reviewers may choose to conduct a qualitative assessment of the results of a systematic review for benefit and harm outcomes. These results may or may not be summarized using meta-analysis. A qualitative assessment is currently the most common approach for assessing the balance of benefits and harms by systematic reviewers and policymakers. A quantitative assessment using a benefit and harm comparison metric may be informative for the third stage of decisionmaking (see Figure 1).

If systematic reviewers use a quantitative approach, they should say so explicitly. Systematic reviews should clearly explain whether or not they choose to use a quantitative approach that will provide a benefit and harm comparison metric. If a quantitative approach is chosen, the systematic review protocol should outline which approach is chosen and the justification behind the choice. The choice of a particular approach has implications for: (1) the type of evidence (e.g., randomized trials and/or observational studies) that needs to be identified; (2) the electronic and/or non-electronic search strategies; (3) the involvement of stakeholders and if their preferences need to be considered; (4) the type of outcome data to be extracted or requested from primary studies; and (5) the methodological-statistical expertise needed to conduct the analyses.

## Conduct and Reporting of Systematic Reviews

### Preserve Information When Reporting on Benefit and Harm

An information-preserving approach allows the users of systematic reviews to calculate any metric that compares the event rates in two treatment groups. For example, if reviewers present the event rate (e.g., number of events per 1,000 person-years) of an outcome for each treatment group, it allows users to calculate both risk difference and relative risk and is an information-preserving approach. If reviewers only presented the relative risk, it would not be possible to obtain the risk difference. This is reiterated in the AHRQ Methods Guide for Comparative Effectiveness Reviews, which advises that reviewers should report absolute risks along with relative risks.9 Systematic reviewers should conduct the quantitative assessment of benefits and harms on an absolute scale or use both absolute and relative scales. Another example of this principle is in how reviewers combine outcomes. An information-preserving approach would report the event rates for each individual outcome in each treatment group. Combining all the benefit outcomes into a single outcome (e.g., a composite outcome) and only reporting this composite outcome is not information-preserving.

### State How Decisions About Comparisons, Outcomes, Baseline Risks, and Time Horizons Were Made To Increase Transparency

To enable end users to replicate the methods, systematic reviewers should state how they made decisions about comparisons, outcomes, baseline risks, and time horizons to increase transparency of reporting on benefits and harms. Systematic reviews should aim to consistently report the time horizon of included studies. Reviewers also need to provide the sources of data and assumptions used in conducting a benefit harm assessment.

For example, if reviewers use the NNT and NNH approach, systematic reviews should not only provide information on the underlying meta-analysis for the intervention that informed the relative or absolute risk estimates, but also information on whether or not the baseline rate used was the control event rate in the trials or some other population-based study. The reviewers need to indicate the time periods that relate to the estimates. Any additional assumptions about estimating NNT and NNH should be clarified. Such assumptions could include the assumption that benefits and risks are constant over time. Some of these assumptions are unverifiable and inherent to the respective quantitative approach. For example, some methods require the assumption that effect estimates do not vary across populations. On the other hand, assumptions about constant risks over time, or variations in the contour of benefit and harm over time, could be verified with either individual patient data or closer examination of summary data. Assumptions should be justified to enable end users to determine whether the assumptions fit their needs and whether the source of the estimates is applicable to their context.

### Convey Sampling Uncertainty and Uncertainty in the Strength of the Evidence

Systematic reviewers should qualitatively describe the various sources of uncertainty surrounding the balance of a benefit harm assessment. Reviewers should be as explicit as possible concerning the applicability of the evidence on harm to particular subgroups such as older adults or people with important comorbidity.

Previous work has noted that uncertainty can arise from at least five different types of issues: inherent uncertainty regarding the future, uncertainty regarding validity, uncertainty regarding significance for the individual, uncertainty related to complexity (e.g., that the risks for several outcomes each change with time), or uncertainty related to what is not known.88 Reviewers should pay particular attention to sampling uncertainty and report not only point estimates of effect, but also report confidence intervals around benefit and harm estimates as recommended in the AHRQ Methods Guide for Comparative Effectiveness Reviews. To convey uncertainty around the strength of evidence, reviewers should provide an explicit strength of evidence grade for each important benefit and each important harm. Probabilistic analysis and sensitivity analysis are two examples of quantitative approaches that reviewers can use to explore uncertainty regarding the validity of effect estimates. Reviewers may not have enough information to estimate the potential effects of all sources of uncertainty, but they should at least acknowledge each source of uncertainty. Decisionmakers then can make decisions with better awareness of what is not known with certainty, such as the long-term effects of treatments.