# Methods

Our team, consisting of clinicians, epidemiologists, and statisticians, first addressed the first two objectives of this project: (1) to identify challenges for assessing benefits and harms in systematic reviews, and (2) to describe methodological characteristics of existing quantitative approaches for assessing benefits and harms in systematic reviews.

We selected a sample of evidence reports published between 2007 and 2011 from the Effective Health Care Web site of the Agency for Healthcare Research and Quality (AHRQ),3 4 and two recent systematic reviews that reported on benefits and harms.5,10-12 The team then searched for quantitative approaches for assessing benefits and harms, examining key articles garnered from the team's reference libraries, including prior work on methods for describing benefits and harms. We did not perform a formal systematic review of the literature because a review on the topic of benefit harm assessment already existed, and because our focus was on organizing available approaches in the context of systematic reviews.13-17

We capitalized on the work done previously and created a list of relevant approaches, which allowed us to concentrate on the main focus of synthesizing information about available methods for use in systematic reviews.13 The team looked for articles that quantitatively assessed at least one outcome each for both benefit and harm of a medical or public health intervention and included approaches that analyzed benefit and harm outcomes separately, as well as approaches that provided a benefit and harm comparison metric for the balance of benefit and harm (e.g., ratio of number needed to treat [NNT] to number needed to harm [NNH]). The team also evaluated articles citing any of the above articles to determine whether they described additional relevant concepts or quantitative approaches. Finally, we screened the reference lists of all included articles for more relevant articles.

One team member led the discussion of challenges, the methodological characteristics of quantitative approaches, values and preferences, and principles. All team members were involved in the weekly discussion. Subsequently, we circulated notes from the meeting until saturation of themes and consensus was achieved on operational terms. Our team discussed the existing quantitative approaches for benefit harm assessment in 12 1-hour sessions.

The discussion helped us to define the properties that characterize quantitative approaches for assessing benefits and harms. To develop an organizing framework for quantitative approaches, the team iteratively defined a list of key characteristics to describe existing quantitative approaches for assessing benefits and harms and that allowed comparisons across the quantitative approaches. For example, the team identified the types of data needed for each quantitative approach, the assumptions underlying the quantitative approaches, the benefit and harm comparison metrics used, and the way researchers communicate the results of the benefit harm assessment to decisionmakers. In addition, the team defined desired properties of quantitative approaches for benefit and harm assessment that were beyond statistical considerations, such as the populations considered, the comprehensiveness and quality of data collected, and the sources of evidence considered. The team also recognized and recorded limitations inherent in each of the quantitative approaches that could threaten their usefulness. We described all quantitative approaches using the final list of key characteristics and unified the approaches for comparison in a table.

The team shared these key characteristics with a diverse panel of external experts (the Technical Expert Panel). The expert panel was composed of systematic reviewers, experts in patient preferences and members of other Evidence Based Practice Centers, including end-users of systematic reviews.

Starting with the list of key characteristics, the team identified the properties a quantitative approach for benefit harm assessment should possess to be valid and relevant to decisionmakers. In doing so, the team considered the advantages and disadvantages of existing quantitative approaches and how the approaches could be refined to have as many desirable properties as possible.

For Objective 3, our team considered the role of values and patient preferences in systematic reviews and quantitative approaches to assessing benefits and harms. We devoted three additional weekly sessions to evaluating the implicit and explicit role of values and preferences during the process of evidence generation and evidence synthesis. These included evaluating the role of values and preferences in moving from evidence generation to development of evidence-based medicine tools. We evaluated how choices of investigators, systematic reviewers, and policymakers may impact the assessment of benefits and harms in systematic reviews.

The team reviewed the results for Objectives 1 through 3 and developed principles for assessing the balance of benefits and harms in systematic reviews (Objective 4). To guide systematic reviewers who plan to conduct or inform a quantitative benefit harm assessment, these principles addressed various stages of the systematic review process. The team revised these preliminary principles after electronic review and input from the Technical Expert Panel.