# Methodological Characteristics of Existing Quantitative Approaches for Assessing Benefit and Harm

Past reviews of quantitative approaches for benefit and harm assessment have not organized the approaches according to important characteristics of the approaches.13,16,17 Also, none of the reviews to date have considered the applicability of these methods for systematic reviews and meta-analysis. Systematic reviewers need a framework that recognizes the key characteristics of quantitative approaches, and organizes them accordingly. Such a framework could help to clarify the common and different elements of existing approaches, and guide further development of benefit harm assessments. A framework could also help to guide investigators and systematic reviewers when choosing an approach to benefit harm assessment. Most quantitative approaches are based on primary datasets, where investigators had control over study design, outcome selection, and individual patient data. We sought to review available quantitative approaches to assess the benefits and harms of medical and public health interventions, and to develop a framework for organizing the quantitative approaches to benefit harm assessment that would help systematic reviewers more effectively choose an appropriate method.

## Literature Review and Classification of Quantitative Approaches for Benefit Harm Assessment

The team identified 16 quantitative approaches for benefit and harm assessment. Figure 2 (Framework for Organizing Quantitative Approaches) shows how we grouped these approaches into two broad categories. One category comprises simpler approaches that typically deal with one outcome for benefit (e.g., prevention of stroke) and one outcome for harm (e.g., gastrointestinal bleeding). These approaches can deal with composite outcomes that summarize multiple endpoints. Also, the approaches considering a single benefit and a single harm outcome can deal with several outcomes, but only in separate analyses.

Figure 2 Framework for organizing quantitative approaches

BLRA = benefit-less-risk analysis; Gail/NCI = Gail/National Cancer Institute approach: INHB = incremental net health benefit; MAR = maximum acceptable risk; MCE = minimum clinical efficacy; MCDA = multicriteria decision analysis; MERT = minimum target event risk for treatment; NCB = net clinical benefit; NNT = number needed to treat; NNH = number needed to harm; NNTt = threshold number needed to treat; PSM = probabilistic simulation methods; Q-TWiST = (quality-adjusted) time without symptoms and toxicity; QFRBA = quantitative framework for risk and benefit assessment; RBC = risk–benefit contour; RBP = risk–benefit plane; RV-NNT = relative value adjusted number needed to treat; TURBO = transparent uniform risk benefit overview; SPM = stated preference method;

Figure 2 is the framework for organizing quantitative approaches. Figure 2 defines the steps of benefits and harms assessment. It includes, reporting of benefits and harms, quantitative approaches, decision making at the population level, and decision making at the individual level.

A second category includes more complex approaches that consider multiple benefits and harms in one analysis. However, some of these approaches can be used for both single and multiple outcomes.

In Figure 2, we categorized these approaches according to how the medical literature typically uses them (e.g., number needed to treat [NNT] and number needed to harm [NNH] are typically used for single outcomes). We listed a few of them in two categories if we could not clearly categorize them (e.g., minimum target event risk for treatment, and quality-adjusted time without symptoms or toxicity [Q-TWiST]). Figure 2 also demonstrates that a benefit and harm comparison metric that puts all outcomes on a common scale further distinguishes between approaches.

Some systematic reviews might not need quantitative approaches at all. We can think of two such situations: (1) systematic reviews that exclusively focus on either benefits or harms; or (2) treatments where benefits are much greater than harms or vice versa). This situation is relatively rare. Otherwise, systematic reviewers need to compare carefully the results for benefit and harm outcomes before deciding against a quantitative benefit harm assessment.

One example is exercise therapy32 for patients with chronic obstructive pulmonary disease. Exercise therapy provides great benefit to patients (e.g., improvement of symptoms, exercise capacity, and quality of life) with very little harm (e.g., small risk of accidents during unsupervised exercise) or inconvenience (e.g., going to a rehabilitation center). In such situations, the decisionmaking is very unlikely to change if the results from a quantitative benefit harm assessment are available. However, systematic reviewers should not make premature judgments about the need for a quantitative benefit harm assessment based on their own preferences for or against certain interventions.

For a particular systematic review, not all 16 approaches are a sensible option. Usually, the best approach depends on the number of outcomes, the need for a benefit and harm comparison metric, and the quality and quantity of available data Table 2).

Table 2 Organizing framework of existing quantitative approaches for benefit harm assessment

Key characteristics | BLRA | Boers | Gail | INHB | MCDA | MCE | NCB | NNT & NNH | PSM | QFRBA | Q-TWiST | RBC | RBP | RV-NNT | SPM & MAR | TURBO | Number of approaches having each characteristic
Types of data
Require individual patient data | Yes | Yes | No | No | No | No | No | No | No | No | No | No | No | No | Yes | No | Yes: 3 No: 13
Types of analyses
Data driven versus simulation | DD | DD | DD/S | DD | DD | DD | DD/S | DD | S | DD | DD | DD/S | DD | DD | DD | DD | DD: 15 S: 4
Types of B&H metrics
Absolute versus relative measures versus QALY versus other | Other | A | A | QALY | A / R | A | A | A | A | A / R | A/QALY | A | A | A | A | A / R | A: 14 R: 3 QALY: 2
Assumptions
Put B&H outcomes on same scale | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | Yes: 12 No: 4
Uncertainty estimates for B&H assessment | No | No | No | No | Yes | No | Yes | No * | Yes | NA | No | Yes | No | No | NA | No | Yes: 4 No: 10 NA: 2
Joint distribution of B&H outcomes considered for uncertainty estimates | No | NA | P | NA | No | NA | No | No | P | NA | NA | P | P | No | NA | NA | P: 4 No: 5 NA: 7
Multiple endpoints versus composite outcomes for B&H | M | Comp | M | M | M | M | M | M/Comp | M | M | M | M | Comp | M | M | Comp | M: 13 Comp: 4
Consideration of preferences
Explicitly considers preferences for B&H assessment: | Yes | No | Yes | No | Yes | Yes | Yes | No | Yes | No | Yes | No | No | Yes | Yes | No | Yes: 9 No: 7
Types of presenting benefit risk balance
B&H difference versus B&H ratio versus Time gained/lost vs. B&H graphic versus other | D | Graph | D | D | D, Ratio | D | D | Ratio | D | D, Ratio | Time, D | Graph | Graph | Ratio | D | Graph | D: 10 Ratio: 4 Graph: 4 Time: 1

* For some variants of the NNT approach such as NNTt and the minimum target event risk for treatment (MERT), uncertainty estimates exist53

A = absolute risk metric; B&H = benefit harm assessment; BLRA = benefit-less-risk analysis; D = difference; DD = Data Driven; Graph = graphic; INHB = incremental net health benefit; O = other; M = multiple; MAR = maximum acceptable risk; MCDA = multicriteria decision analysis: MCE = minimum clinical efficacy; NA = not applicable; NCB = net clinical benefit; NNT = number needed to treat; NNH = number needed to harm; P = possible; PSM = probabilistic simulation methods; QFRBA = quantitative framework for risk and benefit assessment; Q-Twist = (quality-adjusted) time without symptoms and toxicity; R = relative risk metric; RBC = risk–benefit contour; RBP = risk–benefit plane; RV-NNT = relative value adjusted number-needed- to-treat; S = simulation; SPM = stated preference method; TURBO = transparent uniform risk benefit overview

To facilitate the comparison of these approaches in the context of a systematic review, the team selected, as examples, four approaches to give a more detailed description. The NNT/NNH ratio is an example of an approach where a single benefit outcome and a single harm outcome are of interest. The Multicriteria Decision Analysis considers multiple outcomes. The Gail/National Cancer Institute (Gail/NCI) method places multiple outcomes on a single benefit and harm comparison metric. Finally, the risk-benefit contour is a graphical approach that visualizes the probability of harm and benefit and associated uncertainty. A more extensive evaluation of some of these approaches will be presented in our next report.

### Number Needed To Treat and Number Needed To Harm

The number needed to treat (NNT) and its harm counterpart, the number needed to harm (NNH), are perhaps the most widely used measures of benefit and harm when presented separately in systematic reviews. Also, practice guidelines most commonly use NNT when discussing benefit and harm balance. NNT and NNH refer to the number of individuals that need to be treated over a specified period of time for one person to benefit or be harmed, respectively, and will therefore vary as the specified treatment time varies.

The NNT and NNH are almost always presented separately (i.e., not using a benefit and harm comparison metric such as the ratio of number-needed-to treat [NNT] to number-needed-to harm [NNH], hereafter referred to as the NNT/NNH ratio). For example, the Clinical Practice Guidelines on Antithrombotic Therapy in Atrial Fibrillation of the American College of Chest Physicians present NNTs based on a systematic review of RCTs of oral anticoagulant therapy compared with no antithrombotic therapy: The efficacy of warfarin was consistent across studies with an overall relative risk reduction of 68 percent (95% confidence interval, 50 to 79 percent) analyzed by intention-to-treat.33 The absolute risk reduction implies that 32 ischemic strokes will be prevented each year for every 1,000 patients treated (or 32 patients needed to treat for 1 year to prevent one stroke, NNT = 32).

In contrast, studies do not commonly use the NNT/NNH ratio. One reason for the rare application of this benefit and harm comparison metric may be that investigators or guideline developers are reluctant to implicitly weigh benefit and harm outcomes equally on the same scale because of uncertainty about their relative importance.

### Multicriteria Decision Analysis

The analytic hierarchy process (AHP) is an example of a multicriteria decision analysis approach. We use the AHP to explain the principle of a multicriteria decision analysis using the systematic review of oral hypoglycemic agents for type 2 diabetes. The first step in AHP analysis consists of defining the goal of the decision, the alternatives being considered, and the criteria that determine how well the alternatives can be expected to meet the goal.34,35 Studies organize these into a hierarchical decision model with the goal of determining the best treatment for type 2 diabetes.

Operationally, we could define two criteria as being necessary for determining the best treatment: (1) it maximizes benefits via glucose reduction, and (2) it minimizes harms or medication related adverse effects. We could divide the criteria on maximizing benefits into three sub-criteria: health-related quality of life, microvascular benefit (such as improvements in incidence of neuropathy, nephropathy, and diabetic retinopathy), and potential macrovascular benefit. We could subdivide the criteria on minimizing risk into six sub-criteria of medication-related adverse events: congestive heart failure, fractures in women, macular edema, bladder cancer, myocardial infarction, and hypoglycemia.

In the second step, reviewers obtain information about how well the alternatives can be expected to fulfill the decision criteria from the systematic review. The third step consists of two parts: (1) comparing the ability of the alternative treatments to fulfill the prespecified criteria (maximizes benefit and minimizes harm), using standard AHP pair-wise comparisons, and (2) assessing the importance of these criteria to the decision goal. In the fourth step, reviewers take the scales created in step three and combine them to create a summary score indicating how well they can expect alternative treatments will meet the decision goal. The fifth step consists of sensitivity analyses to explore the effects of changing the estimates or judgments used in the original analysis.

The main advantages of AHP are: the use of the summary score; the incorporation of uncertainty; and the option to explore the extent to which every criterion, judgment, and weight contributes to that score.

### The Gail/National Cancer Institute

Some decisionmaking contexts are more complicated because of the many different treatment outcomes as well as many sources of uncertainty they include. A well-known example is the use of tamoxifen for the prevention of breast cancer. Tamoxifen reduces the risk for invasive and in situ breast cancer substantially, and it also prevents some bone fractures.36 However, it also increases the risk for endometrial cancer, stroke, and pulmonary embolism.

The National Cancer Institute (NCI), under the leadership of Dr. Mitchell Gail, developed an approach for dealing with multiple outcomes. Rather than simplifying the benefit harm assessment to single outcomes, they estimated the probability of various outcomes for women with and without tamoxifen therapy over a period of 5 years. Based on observational studies, surveillance registries, and placebo arms of RCTs, they first estimated the expected number of invasive breast cancers, in situ breast cancers, hip fractures, endometrial cancers, strokes, pulmonary emboli, deep vein thromboses, Colles' fractures, spine fractures, and cataracts in the absence of tamoxifen treatment (each per 10,000 women and over 5 years). They estimated these numbers overall and also stratified for different age and race categories.

They then estimated, for each outcome and based on the Breast Cancer Prevention Trial, the expected number of the same outcomes with tamoxifen treatment (each per 10,000 women and over 5 years).14 Here, they also estimated the numbers overall and stratified for different age and race categories. To put all outcomes on the same scale, but to also consider the relative importance of these outcomes, they categorized the outcomes into life threatening, severe, and other outcomes; and suggested weighting them with some factor (e.g., 1 for life threatening, 0.5 for severe, and 0 for other outcomes). These categories and weights could be modified according to patient or treatment-provider preferences. Sometimes, it may be difficult to choose the weights, because of a lack of evidence on patient preferences. In such cases, sensitivity analyses should take different weights into consideration.

Ultimately, researchers present the results of the benefit harm assessment as the net number of events prevented per 10,000 women treated with tamoxifen over a period of 5 years. For example, for a 45-year-old woman with her uterus and a 4 percent risk of invasive breast cancer over 5 years, the net number of events prevented (weighted by clinical importance) was 196 per 10,000 women with this profile. The expected number of prevented invasive and in situ breast cancers was 299 per 10,000 women, with 59 per 10,000 women having some harm such as endometrial cancer, stroke, pulmonary embolism, or deep vein thrombosis. The net benefit (benefit minus harm events) varied considerably and was positive for some profiles but negative for others (e.g., black women age 50-59 years and a 5-year risk of invasive breast cancer of 4 percent).

### Risk-Benefit Contour

The risk–benefit contour plot is a graphical method used to visualize the probability of benefit and harm and associated uncertainty. It portrays the probability of benefit for a new treatment compared with another treatment against the probability of harm for that new treatment as compared with another treatment.37

The probabilities that tell us how likely it is that a treatment is beneficial can be derived from standard statistical software or a Z table of normal values. For example, the 95% CI of a (hypothetical) relative risk of 0.75 may range from 0.50 to 1.00, which tells us that we can have 5 percent confidence that the effect is outside this range (half of which [2.5 percent] is above 1.00). Thus, for each effect estimate, the probabilities of an effect can be calculated based on the published reports of RCTs (i.e., point estimates and 95% CIs).

Contour lines portray the shape of this relationship for a number of different probabilities and confidence levels. As shown in Figure 3, a Risk-benefit Contour Example, a clinician might recommend the new treatment if there is at least a 10 percent survival benefit compared with another treatment, and if the probability of severe harm is not increased by more than 30 percent, compared with the other treatment. The contour lines show a 70 percent probability that the new treatment provides 10 percent survival benefit, and not more than 30 percent chance of severe harm, compared with the treatment alternative.

Figure 3 Risk-benefit contour example

Adapted from: Fig 6, in Shakespeare et al. Lancet 2001 37

Figure 3 is a Risk-benefit Contour Example.

The clinician and patient may or may not accept the uncertainty associated with a 70 percent probability when deciding for or against the new treatment. The risk-benefit contour plot is a way to express uncertainty associated with certain pairs of benefit and harm.

## Description of Key Characteristics of 16 Quantitative Approaches for Benefit Harm Assessment

Quantitative approaches differ in more than just the number of outcomes considered and the use of a benefit and harm comparison metric. Therefore, we focus here on additional characteristics of benefit harm assessment approaches that systematic reviewers should consider when choosing the approach for a specific key question and context. Previous reviews have discussed some of these methods, but not in the context of systematic reviews.13

For the purpose of this report, we identified the following six key characteristics of quantitative approaches for benefit harm assessment:

1. The type of data needed: Individual patient data have advantages over the aggregate data typically available for evidence synthesis. An individual study should have information on the occurrence of benefit and harm outcomes for each patient as well as on their temporal sequence. For each patient, data can describe the cumulative occurrence of benefit and harm outcomes over time as well as their correlation. For example, phosphodiesterase-4 inhibitors are new drugs for patients with chronic obstructive pulmonary disease that aim at reducing exacerbations, but they also have some gastrointestinal toxicity. Patients who take these drugs regularly have a lower risk for exacerbations than those who do not take them, but they are also at greater risk for nausea, diarrhea, and abdominal pain.38 A patient with greater susceptibility to gastrointestinal toxicity is more likely to have more frequent gastrointestinal symptoms over the course of treatment. Patients on the lower dose and those who are less susceptible experience a lower frequency of adverse effects. An important aspect of the availability of such individual data is that researchers can consider the joint probability of benefit and harm outcomes.
2. The type of analyses: Analyses for benefit harm assessment could include any type of statistical analysis. We can make a major distinction, however, between approaches that are data driven (deterministic) and approaches that use modeling (e.g., stochastic), where data are not described by unique values, but rather by probability distributions.
3. The type of benefit and harm comparison metric: Studies can use comparison metrics based on absolute differences or relative differences. Alternatively, studies could use quality-adjusted life-years as a benefit and harm comparison metric. Each metric has its advantages and disadvantages and the choice depends on the decisionmaking context.
4. Assumptions: In quantitative approaches to benefit harm assessments, researchers usually make assumptions. For example, if they use a benefit and harm comparison metric, the assumption is that the outcomes considered are the ones that inform decisionmaking and that it makes sense to combine the outcomes on a single scale. It may not make sense to combine a surrogate outcome (e.g., lung function) and quality of life on the same scale. Outcomes may not be of equal importance and can be weighted according to the importance to patients. Other assumptions relate to the joint occurrence of separate outcomes. Some approaches assume that separate outcomes occur independently, which may or may not be justifiable.
5. Consideration and incorporation of patient preferences: Some quantitative approaches explicitly consider patient preferences for different outcomes when weighing the benefits and harms. For example, aspirin may prevent 10 major strokes in 1,000 middle-aged men treated for 10 years, as compared with no aspirin prevention.39 Aspirin may also cause an additional 40 major gastrointestinal bleedings over the same prevention period, as compared with no aspirin prevention. If patient preferences are equal for major stroke and major gastrointestinal bleeding, it would not be advisable to use aspirin in middle-aged men. However, if patients weigh major stroke as being 10 times as important as major gastrointestinal bleeding, aspirin may provide more benefit than harm.
6. Formats for presenting benefit and harm balance: Studies can use various formats to present the results of the quantitative benefit harm assessment. The studies can present the benefit and harm balance as a difference in the number of events between a treatment options, or they can describe it as a ratio. The studies might also express the balance by the time gained or lost without symptoms through a treatment, or use graphics that depict the benefit and harm balance for patients at different outcome risks or based on other patient characteristics.

## Brief Description of Key Characteristics of Each Approach

Here we first summarize the 16 approaches according to key characteristics and then provide a brief discussion of each approach. Three approaches require individual patient data (See Table 2 for a summary of all of the approaches), and 13 approaches do not require individual patient data. Fifteen of the approaches are data driven, but 3 of the 16 may also use simulation while one approach, probabilistic simulation, is based entirely on simulation. Twelve of the 16 approaches put benefit and harm outcomes on the same scale to provide a benefit and harm comparison metric. Only 4 approaches provide measures of uncertainty around the benefit and harm comparison metric, although considering uncertainty is likely to be of importance for decisionmakers and organizations making treatment recommendations. Four approaches could consider the joint distribution of benefit and harm outcomes for the estimation of uncertainty, but many examples using these 4 approaches do not consider the dependence between benefit and harm, and only consider their marginal distributions (i.e., they consider them to be independent). Four approaches use composite outcomes for benefit and composite outcomes for harm; while 13 approaches use multiple outcomes (NNT and NNH can use both). Nine of the 16 approaches explicitly incorporate patient preferences.

The team found that most of the approaches could be used in systematic reviews since most used aggregate data. This important finding means that systematic reviewers have a wide range of quantitative approaches for benefit and harm assessment and can choose the most appropriate and feasible approach for a specific question.

### Benefit-Less-Risk Analysis

Benefit-less-risk analysis (BLRA) combines benefit and harm into a single metric, and was designed primarily for clinical trials.40 BLRA takes advantage of individual patient data. For each patient of a trial (who is under some or no treatment), researchers record a benefit as yes = 1 or no = 0, and express the harm as a value between 0 and 1.

This type of analysis presents the relationship between benefit and risk as risk subtracted from benefit (e.g., 1 for benefit – 0.2 for harm). BLRA thus allows for statistical testing of comparisons between treatment groups and can consider patient preferences, expressing the relative importance of benefit and harm outcomes. If a systematic review used this method, the review would need to gather individual patient data from the primary studies.

### Boers' 3×3 Table

This quantitative approach does not require any statistical models but offers a way for organizing outcome data on the same scale.41 This approach needs individual patient data. Researchers split the outcomes of patients into three categories (minimal, moderate, or major benefit, and minimal, moderate, or major harm) and display the number of patients with a certain benefit harm profile (e.g., major benefit and minimal harm) in a 3×3 table. The approach does not consider treatment effects directly, since studies would need a separate 3×3 table for each treatment group. As a consequence, no measures of uncertainty are available. It does not consider patient preferences, but includes instead the clinicians' view or agreement as to what constitutes minimal, moderate, or major benefit or harm, respectively.

The method is feasible for both single trials and systematic reviews. A disadvantage is that, although each table is simple and easy to read, it requires readers to somehow estimate treatment effects across tables or to provide a benefit and harm comparison metric. Thus, the method challenges rather than facilitates conclusions concerning benefit and harm.

### The Gail/National Cancer Institute

This approach is probably one of the most comprehensive approaches for benefit and harm assessment, since it considers various data sources to balance the benefits and harms of a treatment. As described earlier in this report, the Gail/NCI approach calculates a benefit and harm comparison metric as the sum of benefit and harm outcome rates per patient profile. It incorporates patient preferences by looking only at one severity grade or by weighting outcome rates that reflect patient perception of very severe, severe, or moderately severe events.

It does not provide estimates of uncertainty arising from sampling variation (although additional analysis such as probabilistic simulation can provide measures of uncertainty) or from combining different data sources of different methodological quality. However, by looking at benefit and harm comparison estimates across patient profiles, one gets an impression of how the net benefit changes, even qualitatively, as the baseline harm changes.

This approach is resource-intensive because it considers multiple data sources and multiple outcomes. However, a comparative effectiveness review could provide an ideal basis for this approach if reviewers collected additional data, such as risk for outcome estimates from observational studies. The U.S. Preventive Services Taskforce used a similar, but simplified, approach to make recommendations on the use of aspirin for the prevention of myocardial infarction. Similar to the tamoxifen example, it estimated the number of benefits (myocardial infarction avoided) and harms (bleedings) per 1,000 men or women based on observational data, and it combined the evidence on treatment benefit and harm with these outcome estimates. The benefit and harm comparison metric provided the number of net events (benefit minus harm) prevented or in excess when aspirin was used.39

### Incremental Net Health Benefit

Incremental net health benefit provides a benefit and harm comparison metric (using quality-adjusted life years [QALYs]) to place one or more benefit and harm outcomes on the same scale, and it calculates the difference between benefits and harm between treatments (thus a result greater than 0 is favorable).42,43 A requirement for this approach is either the valid measurement of utilities or the transformation of quality-of-life scores into utilities (which is sometimes inaccurate). Also, it may be difficult to disentangle benefits and harms when using utilities because the utility for any given health state could be based on a combination of benefits and harms.

### Multicriteria Decision Analysis

Multicriteria decision analysis allows for systematic decisionmaking in complex situations involving tradeoffs, by considering various benefits and harms associated with treatments.44,45 This analysis uses a decision-tree model to incorporate benefits from clinical trials and harms such as adverse effects. It allows for input from various stakeholders who may assign different preference weights to the risks and benefits. Multicriteria decision analysis represents an approach to reducing the multidimensionality of benefit harm assessment in a systematic way, and it makes judgments both explicit and transparent.46 It allows for decisionmaking in the presence of uncertainty, and it can incorporate data from multiple sources including systematic reviews.47

The challenges of its application to systematic reviews include getting reliable information on various preferences, agreement on all relevant benefits and harms (and the relative importance and weighting of these outcomes), and the need to specify a decisionmaking context given that systematic reviews are usually conducted to meet the needs of multiple decisionmakers. The flexibility of multicriteria decision analysis also poses challenges for benefit harm assessment since systematic reviews often are unable to provide sufficient evidence on all relevant inputs, especially less tangible inputs (e.g., societal values, opportunity costs) that may alter the harm-benefit balance in a particular decisionmaking context.

### Minimum Clinical Efficacy

Minimum clinical efficacy assesses benefit by comparing benefits and harms on a probability scale, where it applies relative risk reductions (treatment benefits) and risk increases (harms) to absolute probabilities as observed in untreated groups.46,48 It rates an intervention as having at least minimal clinically efficacy if the difference between benefit and harm is positive or above a minimally acceptable threshold. Minimum clinical efficacy can consider relative utilities, but a limitation includes the inability to provide uncertainty estimates for the benefit and harm comparison metric.

### Net Clinical Benefit

Similar to the Gail/NCI approach, the calculation of the net clinical benefit considers different data sources such as RCTs, observational studies, and patient preferences, and it provides profile-specific benefit and harm comparison estimates.49 Net clinical benefit calculates the benefit and harm comparison metric as the sum of all expected benefits minus the sum of all expected harms. It calculates the benefit from the pooled relative risk reductions (based on meta-analysis) that are applied to patients at different risk for the benefit outcome (e.g., stroke). It calculates the expected harm from the risks for the harm outcome and the patient preferences for the harm outcome. It calculates net clinical benefit using a Bayesian approach where all steps (meta-analysis, calculation of expected benefit, and expected harm) are modeled simultaneously.

A major advantage of this approach is its flexibility with regard to combining different data sources and placing distributions on each parameter. Thereby, researchers can quantify uncertainty around the parameters. Net clinical benefit considers patient preferences for different outcomes, but similar to other approaches, the selection of particular values for preferences has a large impact on the net clinical benefit estimates. Figure 2 categorizes the approach as an approach that considers only single benefit and harm outcomes, because published applications of the approach considered only one benefit and one harm outcome. The approach offers, theoretically, enough flexibility to consider multiple outcomes.

### Number Needed To Treat and Number Needed To Harm

NNT and the NNH are the number of individuals who need to be treated over a specified period of time for one person to experience the benefit or the harm, respectively.50,51 NNT and NNH depend on baseline risk (and are thus sensitive to different patient profiles) and the degree of relative risk reduction provided by the intervention, which is often assumed to be constant across the disease spectrum but may actually vary.

Studies cannot calculate NNT and NNH for continuous outcomes unless such outcomes are dichotomized. Systematic reviews often use NNT and NNH as a measure of benefit and harm. Studies can calculate NNT and NNH for single outcomes (e.g., NNT for exacerbations vs. NNH for fractures) or for composite outcomes for both benefit and harm.

An advantage of this method is that it usually keeps benefit and harm separate, and it leaves room for incorporation of preferences by decisionmakers and consideration of multiple outcomes. Studies can calculate NNT to NNH ratios (NNT/NNH ratios) or NNT to NNH differences. Since the concept of NNT is one of frequency and not of importance, studies should only calculate NNT/NNH ratios or NNT to NNH differences for outcomes of similar importance, unless they are weighted.52 When studies calculate an NNT/NNH ratio or NNT to NNH differences as a benefit and harm comparison metric, researchers assume their independence and may need to extrapolate the ratio or difference so that they refer to the same time period.

Extensions of the NNT/NNH ratio approach are the threshold NNT (NNTt), the minimum target event risk for treatment, and the subject-year adjusted NNT.53 The NNTt reflects the point at which the risks and costs of a clinical intervention balance the benefit, and the minimum target-event risk for treatment defines the minimum target-event risk at which the intervention is justified. Subject-year adjusted NNT refers to the denominator as being subject-years instead of participants, to better account for time on treatment for participants. For example, if there are two events per 1,000 subject-years in the control group and one event per 1,000 subject-years in the intervention group, the NNT is 1,000 subject-years, which means that, with treatment, one fewer event would occur with every 1,000 subject-years.

Methods for providing uncertainty for these benefit and harm comparison metrics are available.53 The NNT/NNH ratio, NNTt, and minimum target-event risk for treatment all are feasible within a systematic review context.

### Probabilistic Simulation Methods

The probabilistic simulation method employs probabilistic simulations for benefit and harm comparison estimates using Monte Carlo methods. The probabilistic simulation method estimates the incremental benefit versus the incremental harm for only one benefit and one harm outcome in a single model. Multiple outcomes require different models (similar to the NNT/NNH ratio).

This method can incorporate parameters from multiple data sources (e.g., systematic reviews of RCTs and observational studies), patient preferences (e.g., from conjoint analysis), and different patient profiles.54-56 It estimates uncertainty around the benefit and harm comparison estimate, with or without consideration of the joint distribution of benefit and harm (depending on the availability of individual-level data or reporting of covariance). Probabilistic simulation methods therefore may provide a comprehensive approach to assessing benefit and harm.

### Quantitative Framework for Risk and Benefit Assessment

A quantitative framework for risk and benefit assessment reports on benefit and harm separately. It does not provide a benefit and harm comparison metric and uncertainty estimates are only available for the separate treatment effects for benefit or harm outcomes.13

An advantage of this method is that keeps benefit and harm separate, and it leaves room for incorporation of preferences by decisionmakers and consideration of multiple outcomes. Also, a quantitative framework for benefit and harm assessment is probably the way most meta-analyses currently report or discuss the benefit and harm assessment.

### (Quality-Adjusted) Time Without Symptoms and Toxicity

Time without symptoms and toxicity (TWiST) compares treatments in terms of the time gained without symptoms versus the time lost due to the experience of adverse effects.57,58 It puts the benefit and harm on the same scale (e.g., time). Q-TWiST is a further development that converts time into QALYs.59 Here, the benefit and harm comparison metric is the difference between the treatment-associated gain in QALYs and the loss in QALYs associated with adverse effects of treatment. Oncology has widely used Q-TWiST.

The major advantage of this method is the ability to incorporate patient preferences, which may change over time. The method depends heavily on the availability of measurements that estimate the length of time without symptoms that estimate the time during which adverse effects were experienced, and that have the ability to distinguish benefit and harm. For example, quality of life and some preference-based instruments often provide a composite score that already synthesizes the overall experience of a patient. QALYs value health states rather than changes in health states, and lack of a measure of uncertainty around these measurements may limit the usefulness of Q-TWiST. This method may be difficult to apply in a systematic review, since primary studies are unlikely to report QALYs associated with benefits and harms.

### Risk-Benefit Contour

The risk–benefit contour plot is a graphical method for assessing benefits and harms. It portrays the probability of benefit for a new treatment compared with another treatment against the probability of harm for that new treatment (as compared with another treatment).37 Contour lines portray the shape of this relationship for a number of different probabilities and confidence levels. The risk–benefit contour plot is a way to express uncertainty associated with certain pairs of benefit and harm. The plot conveys study-level relationships, and it does not consider the interdependence of the probability of benefit and harm at the individual level.

Although the method does not incorporate weights (representing patient preferences) for each type of outcome, researchers could adapt it to do so. Researchers should probably view risk–benefit contour plot as a way to present data and visualize uncertainty, whereas they can base the underlying analyses that yield the probability estimates on different statistical approaches such as various forms of probabilistic simulation methods.

### Risk-Benefit Plane and Risk-Benefit Acceptability Threshold

Risk–benefit plane, also known as risk–benefit acceptability threshold, displays both separate estimates of benefit and harm and a benefit and harm comparison metric in a simple figure.56 It does not consider the individual level interdependence between benefit and harm.

Using an absolute scale, the probability of benefit (from a comparison between two treatments) is plotted against the probability of harm. Studies call the slope created by a line between the origin and the two-dimensional result the risk-benefit acceptability threshold. This method does not consider outcome weights that would reflect patient preferences.

### Relative Value Adjusted Number Needed To Treat

The major advantage of relative value adjusted NNT over NNT and NNH is that it allows for incorporation of preferences into assessing benefit and harm.46,48 Otherwise, it offers the same advantages as the NNT/NNH ratio approach, and suffers from the same limitations. Systematic reviews would need information on preferences to use this method.

### Stated Preference Method or Maximum Acceptable Risk

Stated preference methods elicit patient preferences for various tradeoffs and their acceptability for treatment. Studies use the stated preference method to survey patients as to the amount of burden from adverse effects they are willing to accept to experience the benefit from treatment (Maximum Acceptable Risk).60-64 Researchers need individual patient data on preferences for these approaches.

The typical method to elicit preferences is discrete choice or conjoint analysis, where respondents have to pick their preferred treatment from two treatment scenarios that characterize the benefit and harm of these treatments. These approaches assume that the attractiveness of a particular treatment is a function of the benefit and harm attributes, which are combined in various ways in different vignettes of the survey.65

### Transparent Uniform Risk-Benefit Overview

The transparent uniform risk-benefit overview (TURBO) diagram displays the factors “R” and “B”. “R” is the sum of the most serious adverse effect (scored from 1–5) and the second most serious adverse effect (scored from 1–2).15 This approach is based on the frequency and severity of the harm outcome. Similarly, “B” is the sum of the primary benefit (scored from 1–5) and the ancillary benefit (scored from 1–2). The approach bases this score on the probability and extent of the benefit outcome. The “T” score represents the benefit and harm comparison metric and ranges from 1 (high “R” and low “B” score) to 7 (high “B” and low “R” score).

Studies typically use the TURBO in a regulatory context (e.g., the European Medicines Agency) and therefore they base it on single trials, but it can easily be extended to systematic reviews. The factors “R” and “B” can be based on absolute or relative measures of treatment effects for which uncertainty estimates are available. However, the “T” score has no uncertainty estimates.

Unlike other approaches, the TURBO explicitly considers not only one, but two outcomes for both benefit and harm that are weighted differently. Challenges to applying the TURBO method include arbitrary selection of the two benefit and harm outcomes from a comprehensive list of outcomes and the way scores (combining frequency and importance of outcomes) are assigned.

## Desired Properties of Quantitative Benefit and Harm Assessment

Based on our review of the characteristics of existing quantitative approaches to benefit and harm assessment, we identified desired properties of quantitative benefit and harm assessments.

### Study Population

A quantitative assessment of benefits and harms should be derived from a study population that covers the range of subjects for which a quantitative benefit and harm assessment is relevant. It should consider the health care setting in which particular decisions are taken, indicators of disease severity, socio-demographics, and comorbidity (e.g., those with two or more chronic conditions). The study population does not need to be particularly broad, but the key is that the study population used in the benefit and harm assessment reflects the target population.

### Selection of Outcomes

Ideally, a benefit and harm assessment should include all benefit and harm outcomes that could influence decisionmaking. The selection of outcomes depends on the decisionmakers and those affected by the decisions, which could be patients, health care providers, policymakers, or payers. For many treatment decisions, multiple benefit and harm outcomes will be necessary.

### Quality of Outcome Measurement

Another desired property of a quantitative benefit and harm assessment is the availability of high-quality data for both benefit and harm outcomes. As mentioned previously, RCTs are commonly designed to provide high-quality evidence and are usually powered to detect statistically significant differences on efficacy or benefit outcomes, but harms often receive less attention in terms of accurate and valid measurement. Therefore, observational studies should also be considered for harm outcomes.

### Outcome Assessment Across Studies

Ascertaining benefit and harm outcomes should be accurate and similar across studies (e.g., how a cardiovascular event, an exacerbation, or pain is defined). Whether this is the case depends much on the disease area. While in some areas benefit and harm outcome measurement is harmonized (e.g., outcome measures in rheumatology)66, the selection of outcomes and their measurement varies widely in other disease areas.

### Study Duration

Any quantitative benefit and harm assessment should include patient outcomes for the entire period of treatment exposure and followup. This means the assessment should include studies that follow patients with an outcome (benefit or harm) until death (if possible). This is a commonly occurring problem especially when the followup is stopped after a benefit-related outcome, since this could result in an underestimation of harms of the intervention.

### Evidence Selection

A quantitative benefit and harm assessment should be based on the best evidence available, and the evidence should be comprehensive. A systematic review should underlie any quantitative benefit harm assessments. In this way, reviewers identify all studies that potentially contribute to the quantitative benefit harm assessment. The quality of the evidence that reviewers consider will depend on the underlying study designs and on the desired properties for the quantitative benefit harm assessment. As a consequence, a tradeoff between experimental and observational data is often necessary. While trials provide a higher quality of treatment effects (for both benefit and harm outcomes), observational studies are often the only source for harm outcomes in relevant populations and over relevant time horizons.67

### Treatment Information

Ideally, time-dependent information on treatment exposures should be considered, because patients may start and stop treatment during a study. Such information may only be available at the evidence generation stage, making it difficult for systematic reviews to include time-dependent information on treatment exposures.

### Provision of a Benefit and Harm Comparison Metric That Considers Multiple Relevant Benefit and Harm Outcomes

Ideally, a quantitative benefit and harm assessment considers all relevant outcomes for benefit and harm and allows for the use of a benefit and harm comparison metric. Potential metrics are QALYs, NNT/NNH ratio, or an event rate (e.g., rate of events prevented or caused by some treatment).14

### Time of Occurrence of Benefit and Harm Outcomes

A quantitative benefit harm assessment should consider that the time of occurrence of benefit and harm outcomes may be different. Sometimes (e.g., for preventive treatments) harm outcomes are likely to precede benefit outcomes, whereas for other treatments, benefit might be experienced earlier than harm. In addition, a quantitative benefit harm assessment should ideally be able to incorporate variability of benefits and harms in relation to time.

### Handling Different Data Types

Quantitative benefit harm assessments should be able to handle different types of data (binary, recurrent, continuous, and time to event). Many quantitative approaches identified here focus on binary outcomes with or without consideration of time to event. They cannot express some health, or patient-important, outcomes (e.g., quality of life or symptoms) appropriately as binary outcomes without substantial loss of information.

### Uncertainty Estimates for the Benefit and Harm Comparison Metric

Uncertainty regarding the benefit and harm comparison metric is likely to be of key importance for decisionmakers and organizations making treatment recommendations. Typically, uncertainty is represented by 95% confidence intervals, but graphical displays such as the risk-benefit contour may express the extent of uncertainty.

As explained earlier in this report, decisionmakers will likely correlate benefit and harm outcomes, and they should take into consideration the potential interdependence of benefits and harms. Uncertainty may also arise from low-quality evidence. Other ways exist to express the uncertainty about the quality of evidence, such as the evidence grading schemes of the U.S. Preventive Services Task Force or the GRADE working group.

### Incorporation of Preferences

A quantitative benefit harm assessment should explicitly state if and how preferences are incorporated. Most of the quantitative approaches identified here do not incorporate preferences, at least not explicitly. In the context of a systematic review, one can gather explicit data on patient preferences through identification of studies that used conjoint analysis or other methods to elicit patient preferences.

### Consideration of Different Patient Profiles

Quantitative approaches like the NNT/NNH ratio, Gail/NCI or Net Clinical Benefit explicitly consider outcome risks. It is likely that the benefit and harm comparison for a drug like aspirin varies substantially according to age and gender since age and gender are associated with the risk for certain outcomes (e.g., myocardial infarction or gastrointestinal bleeding). Therefore, a quantitative benefit harm assessment should take into consideration different patient profiles.

### Communication of Benefit Harm Assessment to Decisionmakers

Studies need to communicate a quantitative benefit harm assessment effectively to decisionmakers so that they can make informed decisions that are in line with their preferences. It is unknown which of the presentation formats are most effective. However, important aspects need to be considered, including: (1) parsing of information that illustrates a transparent and reproducible reduction of multidimensionality, (2) an explicit statement regarding whether preferences are already incorporated into the estimate or how individual preferences can be incorporated, and (3) graphical displays to convey quantitative information including uncertainty.68 A recent paper highlights that, in contrast to most systematic reviews citing benefit and harm in different locations, a conceptual simple visualization of benefit and harm in a single image could enhance communication of the benefit and harm to decisionmakers.68